# Search Strategy

Searches | Results
exp cohort studies/ or exp prospective studies/ or exp retrospective studies/ or exp epidemiologic studies/ or exp case-control studies/ | 1330225
(cohort or retrospective or prospective or longitudinal or observational or follow-up or followup or registry).af. | 1597416
case-control.af. or (case adj10 control).tw. | 150635
ep.fs. | 950004
randomized controlled trial.pt. | 572821
controlled clinical trial.pt. | 160840
randomized controlled trials/ | 73473
Random Allocation/ | 89432
Double-blind Method/ | 196453
Single-Blind Method/ | 23183
clinical trial.pt. | 737920
Clinical Trials.mp. or exp Clinical Trials/ | 275390
(clinic$ adj25 trial$).tw. | 228819
((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. | 221671
Placebos/ | 48502
placebo$.tw. | 233236
random$.tw. | 762140
trial$.tw. | 592575
(randomized control trial or clinical control trial).sd. | 233432
(latin adj square).tw. | 3570
Comparative Study.tw. or Comparative Study.pt. | 1632454
exp Evaluation studies/ | 137267
Follow-Up Studies/ | 440231
Prospective Studies/ | 336648
(control$ or prospectiv$ or volunteer$).tw. | 2488706
Cross-Over Studies/ | 46589
or/5-26 | 4945677
carotid artery diseases/ or carotid artery thrombosis/ or carotid stenosis.mp. [mp=ti, ot, ab, nm, hw, ui, sh, kw] | 28040
carotid arteries/ or carotid artery, common/ or carotid artery, external/ or carotid artery, internal/ | 40463
constriction, pathologic/ | 16579
29 and 30 | 793
(carotid adj5 (stenosis or thrombo$ or disease$ or narrow$ or plaque$ or arterioscler$ or atheroscler$ or narrowing$ or bruit or asymptomatic or silent or lesion$)).tw. | 17408
28 or 31 or 32 | 33069
angioplasty/ or angioplasty, balloon/ or angioplasty, balloon, laser-assisted/ | 18077
Balloon Dilatation/ | 13112
Stents/ | 38010
(angioplasty or stent$ or endovascular).tw. | 80476
(balloon adj5 (dilat$ or catheter$)).tw. | 12185
((endoluminal or transluminal or percutaneous) adj5 (repair$ or intervention)).tw. | 11054
34 or 35 or 36 or 37 or 38 or 39 | 110461
endarterectomy/ | 5915
endarterectomy, carotid/ | 5760
(carotid adj5 endarterectomy).tw. | 7671
1 or 2 or 3 or 4 | 2400448
33 and 44 | 10313
limit 45 to yr=“2008 -Current” | 1773
remove duplicates from 46 | 1610
41 or 42 or 43 | 13458
40 or 48 | 121379
33 and 49 | 10357
27 and 50 | 5298
47 or 51 | 6475
remove duplicates from 51 | 4876
47 or 53 | 6053