# Results

## Identification of Eligible Studies

From our primary electronic database search for RCTs, CCTs and prospective cohort studies reporting cognitive outcomes after selected cardiovascular procedures, we identified 563 references from MEDLINE^®^, 294 references from Cochrane Central Register of Controlled Trials (CENTRAL), and 538 references from Scopus, for a total of 1114 unique references. Of these, we excluded 661 as ineligible during title and abstract review and 428 as ineligible during full-text review (Figure 2), leaving 25 references that met eligibility criteria and were included. An additional 65 references were identified by hand searching reference lists of included articles and review articles; of these, 61 were excluded during title and abstract review and four during full-text review. We searched ClinicalTrials.gov for relevant registered and completed trials and identified 116 additional studies potentially meeting eligibility criteria. Of these, we excluded 115 as ineligible based on title review and one as ineligible based on in-depth review. Altogether, including four followup reports of eligible studies,29–32 these sources generated 25 reports of 21 unique studies that met eligibility criteria (Figure 2).7, 12, 33–51

All eligible studies were published in peer-reviewed English-language journals.

Figure 2 Literature search flowchart

Figure 2. This figure is the literature flow diagram. It describes the literature search and screen processes which is also described in the report text.

## Study Characteristics

### Study Design

Among 21 eligible studies, 17 were RCTs and 4 were prospective cohort studies.34, 38, 48, 50 Treatment duration for the RCTs ranged from 3 to 60 months, with only one trial longer than 12 months.30 Treatment duration for the prospective cohort studies duration ranged from 3 to 72 months, with only one study longer than 12 months.38

### Treatment Groups

Among eligible studies, most (n=15) evaluated cognitive outcomes after CABG. Of the CABG studies, one observational study compared cognitive outcomes between three groups, patients who underwent CABG with extracorporeal cardiopulmonary bypass (i.e. on-pump), those who underwent CABG without extracorporeal cardiopulmonary bypass (i.e. off-pump), and those treated with medical management.38 Each of the other CABG studies were RCTs that compared cognitive outcomes between two different approaches to CABG, including five that compared on- versus off-pump CABG,33, 35–37, 39 three that compared CABG performed under hypothermic conditions versus under normothermic conditions,37, 41, 42 one that compared on-pump CABG using conventional extracorporeal bypass versus minimal extracorporeal bypass,40 one that compared CABG performed under hyperbaric oxygen conditions versus under atmospheric oxygen conditions,43 one that compared CABG using fentanyl versus propofol,7 one that compared CABG using high versus low dose fentanyl,44 one that compared CABG using cell saver versus using cardiotomy suction,45 one that compared CABG with high versus low mean arterial blood pressure maintained during cardiopulmonary bypass,46 and one that compared CABG with preoperative angiotensin-receptor blocker treatment versus CABG with pre-operative placebo.47

Three eligible studies evaluated cognitive outcomes after carotid artery revascularization, including one RCT that compared CEA versus CAS,49 one RCT that compared CEA versus carotid angioplasty,12 and one prospective cohort study that compared CEA versus laparoscopic cholecystectomy.50

Two eligible studies evaluated post-procedural cognitive outcomes between two different approaches to tissue aortic valve replacement (AVR), including one RCT that compared participants assigned to undergo surgical AVR under hypothermic conditions versus under normothermic conditions51 and one observational study that compared surgical versus transapical transcatheter aortic valve replacement (TAVR).34 Another prospective cohort study compared CABG alone versus surgical cardiac valve repair (aortic or mitral) alone or combined with CABG.48

We did not identify any eligible studies that evaluated cognitive outcomes after percutaneous coronary interventions or surgical or catheter-based ablation for atrial fibrillation.

### Cognitive Outcome Measures

Among the 21 eligible studies, none reported post-cardiovascular procedure incidence of clinical dementia, mild cognitive impairment or any other cognitive-related clinical diagnosis.

All studies reported results for one or more neuropsychological tests in multiple cognitive domains and/or results of global cognitive screening tests. Consistent with the recommendations of a 1995 consensus statement on cognitive testing of patients undergoing CABG,2 the most common cognitive domains and individual tests reported within eligible studies are listed below. A description of the main neuropsychological tests used in eligible studies according to their primary cognitive domain tested follows here, though because many neuropsychological tests assess more than one cognitive domain, results for each neuropsychological test are presented in outcomes tables (Appendix D) for each cognitive domain it addresses.

- Attention: n=18 studies (Trail Making Test A, n=16; Digit Span Forward, n=11);
- Memory: n=18 (Rey Auditory Verbal Learning Test, n=9; nonverbal memory tests, n=5);
- Language: n=12 (verbal fluency tests, n=10; Boston Naming Test, n=4);
- Executive: n=20 (Trail Making Test B, n=18; Digit Symbol/Symbol Digit, n=11; Digit Span Backward, n=10)
- Visuospatial functioning: n=7 (Block Design, n=2)
- Psychomotor: n=14 (Grooved Pegboard, n=10).

Unfortunately, studies often did not report which version of a test was used (e.g., WAIS-R versus WAIS-III) and/or which specific test score was reported (e.g., Digit span item subscore versus maximum span) to enable cross-study comparisons or the referencing of participants’ scores with normative information.

In addition to the individual neuropsychological test data, 12 studies specified abnormal absolute or change thresholds for each administered neuropsychological test and then defined incident “cognitive impairment” or “cognitive decline” based on whether participants performed abnormally or worsened by some threshold on some minimum number of these tests (Appendix I). The most frequently used definitions were ≥20 percent and ≥1 SD decline in at least two cognitive tests compared to baseline, respectively. However, some studies didn’t define deterioration, others required change in only one test, and no two studies used the same set of neuropsychological tests.

Eight studies administered global cognitive screening tests, including the MMSE (n=6), MoCA (n=3) and 3MS (n=1), though in some cases these measures were only administered at baseline.

## Participant Characteristics

### Demographics

The 21 eligible studies included 7802 participants (range 46 to 4752). Study participants were predominately male (weighted mean 80 percent) and had a weighted mean age of 68 years (range of means of 65 to 76 years, including means between 65 to 69 years in all but four studies) (Appendix E). In studies that reported data on education, mean years of education was 11 (range 7 to 14 years; 6 studies with 906 participants reporting) and 40 percent of participants attended any post-secondary program (range 13 to 61 percent; 4 studies with 684 participants reporting). In the two trials that reported data on race (574 participants), 92 percent of participants were Caucasian. One study was conducted in both North America and Europe (61 percent of all study participants), six studies were conducted only in North America (17 percent of all study participants), 11 only in Europe (14 percent), and three in Australasia (8 percent).

#### Comorbid Conditions

Few participants in the CABG studies had a past history of stroke. Mean prevalence was 6 percent (range 0 to 8 percent) in 10 studies reporting. In contrast, in the carotid revascularization studies, all participants in two studies12, 49 and half in one study50 had recent symptomatic internal carotid artery stenosis (i.e., ischemic stroke, transient ischemic attack, and/or amaurosis fugax). One of the valve surgery studies excluded patients with prior stroke, while the other two valve studies didn’t report data on pre-procedural stroke history. Prevalence of other co-morbidities included diabetes 39 percent (range of means 0 to 47 percent; 20 studies reporting) and myocardial infarction 36 percent (range of means 9 to 73 percent; 13 studies reporting). Two CABG studies excluded participants with depression, while no other studies reported data on prevalence of depression.

### Cognitive Function

Four studies excluded participants with dementia or an abnormal baseline cognitive screening test29, 41, 47, 50 and two studies excluded participants with mental retardation or a learning disorder.43, 50 Within eligible studies, using age, gender and education data to compare individual study populations with normative data, most participants appeared cognitively intact prior to their cardiovascular procedures as measured by IQ, global cognitive screening tests, and neuropsychological memory tests. However, some participants had baseline deficits on timed tests, including of set shifting (Trails B) and motor performance (Grooved Pegboard).

More specifically, for studies that reported IQ estimates (n=5 studies), baseline scores ranged from 95.8 to 115, all within the normal range. For studies that reported global cognitive screening tests, baseline scores for the Montreal Cognitive Assessment (MoCA) (n=3 studies) and Mini Mental State Exam (MMSE) (n=6 studies) ranged from 23.2 to 27.1 and from 25 to 30, respectively. These are within the normal range, with the exception of the lowest reported scores for each test. Baseline raw scores for the Rey Auditory Verbal Learning Test (RAVLT) sum of learning trials and delayed recall (n=9 studies) ranged from 33.6 to 53.9 and from 6.0 to 8.4, respectively. All these scores are in the normal range except for the study with the lowest sum of learning trials score.

For the timed tests, baseline raw scores for Trial Making Test A (n=16 studies) ranged from 34 to 68.8 seconds while those for Trail Making Test B (n=18 studies) ranged from 82 to 163.7. Based on the demographics for their specific study sample, few study mean scores fell in the impaired range for Trails A but approximately half the study means were in the impaired range for Trails B. In addition, Grooved Pegboard scores (n=10 studies) for the dominant and non-dominant hand ranged from 81.3 to 108 seconds and 97.2 to 119 seconds, respectively, with about half the study mean scores falling in the impaired range based on their individual study demographics.

## Individual Study Risk of Bias

Among the 17 eligible RCTs, ten were rated as having a moderate risk of bias, and seven were rated as having unclear risk of bias (Appendix F). Risk of bias related to randomization was rated low in 12 trials and was unclear in five trials. Risk of bias related to masking of the outcome assessment was rated low in 13 trials, and was unclear in four trials. Risk of bias related to use of intention-to-treat principles was rated as high in 15 trials (e.g., analyses performed in study completers only) and was unclear in two trials. Risk of bias related to selective reporting of prespecified outcomes was rated low in all eligible trials. Fourteen of the 17 trials reported data on withdrawals, which ranged from 6 to 18 percent at 3 months, 5 to 16 percent at 6 months, and 12 to 25 percent at 1 year.

Among the four eligible prospective cohort studies, three were rated as having a high risk of bias, and one was rated as having moderate risk of bias (Appendix F). For similarity of prognostic factors between baseline comparison groups and in study accounting for attrition bias, three studies were rated as high risk of bias and one low risk of bias. Risk of bias related to masking of the outcome assessment was rated as low in one study and unclear in three studies. All studies were rated low risk for selective reporting of prespecified outcomes. All prospective cohort studies reported withdrawals, which were 18 to 19 percent at 3 months in two studies reporting, 32 percent at 6 months in one study reporting, 6 to 17 percent at 1 year in two studies, and 47 percent at 3 years and 37 percent at 6 years in one study reporting.

## Key Question 1

In older adults who undergo selected cardiovascular procedures, what are the associated post-procedural cognitive outcomes (e.g., clinical severity; timing/duration; pattern of cognitive domain impairment)?

### Key Findings

- Only one study in adults aged ≥65 years compared a cardiovascular procedure of interest versus medical management and reported intermediate and/or long-term cognitive outcomes and just three compared one of these procedures with a less invasive alternative. All had substantial quality limitations, with either moderate or high risk of bias.
- Based on these data, insufficient strength evidence from one study suggested that CABG was not associated with any decline in cognitive function in older adults for up to 6 years, both compared to patients managed with medical therapy and compared to a pre-surgery baseline.
- Low strength evidence from 1 study suggested that were no significant differences in cognitive function at 6 months between older adults who underwent CEA versus CAS. While results from a second study also suggested that there were no significant differences at 6 months after CEA versus carotid angioplasty, SOE for this finding was rated insufficient. There appeared no difference within any treatment groups in either of these studies compared to pre-operative levels. Although, risk of incident cognitive impairment appeared lower with CEA than for carotid angioplasty in one small study, this finding was not statistically significant.
- Results from one study suggested that older adults who underwent TAVR were significantly more likely than those who underwent AVR to experience incident cognitive decline at 3 months, but because results may have been attributable to their older age, more limited education, increased morbidity, and differences in outcome definitions between treatment groups, SOE was rated insufficient.

#### Coronary Artery Revascularization

- Insufficient strength evidence from one observational study (high risk of bias) that compared CABG with medical management in older patients with coronary artery disease reported no statistically significant differences between treatment groups in any reported neuropsychological test at 1 and 6 years. Within the CABG and medical management groups, there were small to moderate improvements in memory versus baseline at 1 year, but no difference in any cognitive test versus baseline at 6 years.31, 32, 38
- Though statistical power from this one observational study was low and losses to followup could have favorably biased results in favor of the CABG group, the small effect sizes both within and between the CABG and medical management groups suggest that the intermediate and long-term cognitive impact of CABG in these older adults may be small.
- No eligible RCT or CCT compared CABG with medical management in older adults and reported intermediate or long-term cognitive outcomes.
- No eligible RCT, CCT or prospective cohort study compared PCI with medical management in older adults and reported intermediate or long-term cognitive outcomes.
- No eligible RCT, CCT or prospective cohort study compared different types of coronary artery revascularization procedures with each other (e.g., CABG versus PCI) in older adults and reported intermediate or long-term cognitive outcomes.

#### Carotid Artery Revascularization

- No eligible RCT, CCT or prospective cohort study compared any carotid artery revascularization procedure (i.e., CEA, CAS, or carotid angioplasty) with medical management in older adults and reported intermediate or long-term cognitive outcomes.
- Low strength evidence from one RCT that compared CEA versus CAS in older adults and reported no statistically significant difference between treatment groups for the outcome of change from baseline to 6 months on any individual neuropsychological domain tested.49
- Insufficient strength evidence from one RCT that compared CEA versus carotid angioplasty in older adults and reported no statistically significant difference in risk of incident “cognitive impairment” derived from a composite of neuropsychological test measures or in change from baseline or absolute levels at followup in 10 of 11 individual neuropsychological test results at 6 months.12
- Although both RCTs had limited statistical power and moderate risk of bias, results suggest that if any intermediate-term cognitive differences exist between CEA and either CAS or carotid angioplasty they may be small.
- Insufficient strength evidence from one observational study that reported that older patients who underwent CEA had a small, but statistically significant improvement in mini-mental status exam (MMSE) and Montreal Cognitive Assessment (MoCA) tests of global cognitive function at 12 months versus age and sex-matched individuals who underwent laparoscopic cholecystectomy.50

#### Cardiac Valve Replacement/Repair

- No eligible RCT, CCT or prospective cohort study compared cardiac valve replacement/repair with medical management in older adults and reported intermediate or long-term cognitive outcomes.
- One prospective cohort study reported that older patients who underwent TAVR were significantly more likely to experience clinically significant cognitive decline at 3 months than those who underwent AVR, but because results may have been attributable to their older age, more limited education, increased morbidity, and differences in how this outcome was defined between these two treatment groups, SOE for this result was rated insufficient.
- No eligible RCT, CCT or prospective cohort study compared mitral, tricuspid or pulmonic valve replacement/repair with any control group in older adults and reported intermediate or long-term cognitive outcomes.

#### Ablation for Atrial Fibrillation

- No eligible RCT, CCT or prospective cohort study compared surgical or transcatheter ablation for atrial fibrillation versus each other or versus medical management in older adults and reported intermediate or long-term cognitive outcomes.

#### Combined CV Procedures

- Insufficient strength evidence from one prospective cohort study that compared CABG alone with aortic or mitral valve surgery alone or valve surgery combined with CABG in older adults and reported no statistically significant difference in 13 of 14 neuropsychological tests at 6 months.48

Table 1 Summary of evidence on association of selected cardiovascular procedures versus control group with intermediate and long-term cognitive outcomes in older adults (KQ 1)

Interventions, Studies (Study Quality) | Cognitive Outcomes | Strength of Evidence^*^
Coronary Artery Revascularization
CABG vs. Medical Management 1 prospective, observational study, n=326 (high risk of bias) 31, 32, 38 | Clinically diagnosed: No results reported. Individual neuropsychological (NP) tests: No statistically significant differences between treatment groups in any absolute test score measured at endpoint (range of effect sizes −0.32 to 0.24). No statistically significant differences between treatment groups in mean change from baseline in selected NP tests.^†^ Composite neuropsychological test cognitive impairment (NPCI): No results reported | Clinical: Insufficient Individual NP Tests: Insufficient Composite NPCI: Insufficient
Carotid Artery Revascularization
CEA vs. CAS: 1 RCT, n=140 (moderate risk of bias)49 | Clinically diagnosed: No results reported. Individual NP tests: No statistically significant differences between treatment groups when comparing mean change from baseline in selected NP tests.^†^ Composite NPCI: No results reported | Clinical: Insufficient Individual NP Tests: Low Composite NPCI: Insufficient
CEA vs. Carotid Angioplasty 1 RCT, n=46 (moderate risk of bias)12 | Clinically diagnosed: No results reported. Individual NP tests: No statistically significant differences between treatment groups in any absolute test score measured at endpoint in 10 of 11 measures reported. No statistically significant differences between treatment groups when comparing mean change from baseline in selected NP tests.^†^ Composite NPCI: Appeared lower after CEA vs. carotid angioplasty (18% vs. 38%), but this difference was not statistically significant (RR, 0.47 [95% CI, 0.16 to 1.35]) | Clinical: Insufficient Individual NP Tests: Insufficient Composite NPCI: Insufficient
CEA vs. Laparoscopic Cholecystectomy: 1 prospective, observational study, n=213 (high risk of bias)50 | Clinical cognitive outcomes: No results reported. Individual NP tests: Small but statistically significantly greater improvement from baseline to 12 months in CEA group vs. cholecystectomy group (MMSE [0.3 vs. 0.0, p<.01], and MoCA [1.0 vs. 0.1, p<.01; between group effect size 0.58 33]). Composite NPCI: No results reported. | Clinical: Insufficient Individual NP Tests: Insufficient Composite NPCI: Insufficient
Cardiac Valve Replacement/Repair
CABG vs. Cardiac Valve Replacement with or without CABG: 1 prospective, observational study, n=109 (moderate risk of bias)48 | Clinical cognitive outcomes: No results reported. Individual NP tests: No statistically significant between-group difference in proportion of participants rated as having a deficit for 13 of 14 neuropsychological tests at followup. Composite NPCI: No results reported. | Clinical: Insufficient Individual NP Tests: Insufficient Composite NPCI: Insufficient
AVR vs. TAVR: 1 prospective, observational study, n=64 (high risk of bias)34 | Clinical cognitive outcomes: No results reported. Individual NP tests: No direct comparisons between treatment arms were done. Composite NPCI: Lower after AVR compared to TAVR (6% vs. 28%; p=0.04). | Clinical: Insufficient Individual NP Tests: Insufficient Composite NPCI: Insufficient
Ablation for Atrial Fibrillation
No eligible studies

Abbreviations: AVR = surgical aortic valve replacement; CABG = coronary artery bypass grafting; CAS = carotid artery stenting; CEA = carotid endarterectomy; CI = confidence intervals; KQ = Key Question; MMSE = Mini-Mental State Exam; MoCA = Montreal Cognitive Assessment; NP=neuropsychological; “NPCI” = cognitive impairment as defined from a composite of neuropsychological test results; RCT = randomized controlled trial; RR = risk ratio; SOE = strength of evidence; TAVR = transcatheter aortic valve replacement.

* Examples when evidence is available but SOE may be graded as insufficient include when there is an unacceptably high risk of bias, or there is a major inconsistency that cannot be explained (e.g., Two studies with the same risk of bias with opposite results and no clear explanation for the discrepancy). In addition, SOE may be graded as insufficient when data are too imprecise. This may be the case when the 95% CI is so wide that it cannot exclude either a clinically significant benefit or harm (e.g., lower CI bound

† Selected NP tests included Trail Making A, Trail Making B, Rey Auditory Verbal Learning Test, Grooved Pegboard, and Verbal Fluency. Number of selected NP tests implemented varied between studies and sometimes between intervention groups.

### Detailed Findings

#### Coronary Artery Revascularization

##### CABG Versus Medical Management

We found no RCTs or CCTs and only one prospective cohort study (n=326) that compared CABG versus medical management and reported cognitive outcomes (Appendix G, Table 1).31, 32, 38

In the cohort study, at both 1 and 6 years of followup, there were only small differences in the absolute test scores between either the on-pump or off-pump CABG and medical management groups for any of the individual neuropsychological tests reported (range of effect sizes −0.32 to 0.24) that were not statistically significant (Appendix J, Table 1). In within group comparisons, compared to their test scores prior to the procedure, both the CABG groups and the medical management group had moderate improvements in the Rey Auditory Verbal Learning Test at 1 year (range of effect sizes −0.39 to −0.57) that were statistically significant but that were no longer present at 6 years (Appendix M, Table 1). For other neuropsychological tests, there was a general pattern for small not statistically significant improvements from baseline to 1 year that were no longer apparent at 6 years.

Although this study had low statistical power to detect small differences in neuropsychological test results and the greater drop-out rate in the CABG groups may have biased results in their favor if participants with greater cognitive decline were less likely to followup, study results suggested that CABG was not associated with cognitive decline during followup as long as 6 years and that there were no significant differences in intermediate and long-term cognitive function between the CABG and medical management groups. However, primarily because this study was rated as having high risk of bias, SOE for these results was graded as insufficient.

This study did not report results for incidence of any cognitive-related clinical diagnosis or for incident cognitive impairment as defined by results from any combination of neuropsychological tests (Appendix H, Table 1; Appendix I, Table 1).

##### PCI Versus Medical Management

No eligible studies compared PCI versus medical management in older adults and reported cognitive outcomes.

##### CABG Versus PCI

No eligible studies in older adults compared CABG versus PCI or compared different methods of PCI and reported cognitive outcomes.

Of note, 14 RCTs assigned all participants to CABG and randomized them between two different methods of CABG (e.g., on versus off-pump, surgery under hypothermic conditions versus under normothermic conditions, comparison between different anesthetic agents or doses, or other). These results are presented under Key Question 2.

#### Carotid Artery Revascularization

##### CEA, CAS, or Carotid Angioplasty Versus Medical Management

No eligible studies compared CEA, CAS or carotid angioplasty to medical management of carotid artery disease and reported cognitive outcomes in older adults.

We identified one eligible prospective observational study that compared cognitive outcomes at 3 and 12 months between individuals with either symptomatic or asymptomatic carotid artery stenosis who underwent CEA (n=159) and age and sex-matched individuals without diagnosed carotid stenosis who underwent laparoscopic cholecystectomy (n=68) (Appendix G, Table 3).50 MMSE and MoCA cognitive screening measures were the only cognitive outcomes reported. This study reported statistically significant improvements of mostly small magnitude in the symptomatic CEA group from baseline to both 3 and 12 months (0.4 and 0.3 point improvement on MMSE, respectively, with effect sizes 0.35 to 0.44; 0.9 and 1.0 point improvement on MoCA, respectively, with effect sizes 0.48 to 0.62) (Appendix M, Table 2). These improvements were generally statistically significantly larger than the changes from baseline seen in the laparoscopic cholecystectomy group (e.g. effect sizes for the between-group difference in the mean MoCA changes were 0.52 to 0.58 at 3 months and 0.35 to 0.36 at 12 months) (Appendix J, Table 3). Between the asymptomatic CEA group and the laparoscopic cholecystectomy group, there were no differences in any cognitive measures at any time point, or when comparing change from baseline to any followup time point. This study did not report results for post-surgical incidence of any cognitive-related clinical diagnosis (Appendix H, Table 3), for incident cognitive impairment as defined by a combination of neuropsychological tests (Appendix I, Table 3), or for any individual neuropsychological tests other than the MMSE and MoCA (Appendix J, Table 3). SOE for findings from this study were graded insufficient.

##### CEA Versus CAS or Carotid Angioplasty

We identified one eligible RCT that compared CEA versus CAS (n=140)49 and one that compared CEA versus carotid angioplasty (n=46) (Appendix G, Table 3).12 Neither study reported results for post-surgical incidence of any cognitive-related clinical diagnosis (Appendix H, Table 3).

The trial of CEA versus CAS did not report results for incident post-procedural cognitive impairment as defined by a composite of neuropsychological tests (Appendix I, Table 3). However, it reported that there were no statistically significant differences between treatment groups in change from baseline to 6 months in any individual neuropsychological domain tested (Appendix J, Table 3). SOE for this latter outcome was graded as low.

In the trial of CEA versus carotid angioplasty, risk for incident cognitive impairment at 6 months (as defined by a composite of neuropsychological tests) appeared lower after CEA than after carotid angioplasty. However, this difference was not statistically significant (18 percent versus 38 percent; RR, 0.47 [95% CI, 0.16 to 1.35]) (Appendix I, Table 3). In addition, no statistically significant difference was found between these treatment groups in change from baseline to 6 months or in absolute scores at 6 months in 10 of 11 individual neuropsychological tests measured (Appendix J, Table 3). SOE for the individual neuropsychological test outcomes was graded as insufficient.

Although these two studies were small and may have had limited statistical power to detect between-group differences in cognitive outcomes, available results nevertheless suggest that any differences in 6 month cognitive outcomes between these procedures may be small.

#### Cardiac Valve Replacement

##### Cardiac Valve Replacement Versus No Cardiac Valve Replacement

We identified no eligible study that compared either surgical or transcatheter cardiac valve replacement versus cardiac valve repair or medical management and reported cognitive outcomes.

##### Surgical Versus Transcatheter Cardiac Valve Replacement

We identified no eligible RCTs or CCTs and only one prospective observational cohort study that compared surgical versus transcatheter cardiac valve replacement and reported cognitive outcomes. In this observational study, 17 patients with aortic valve stenosis considered surgical candidates underwent surgical AVR, while 27 with aortic valve stenosis who were significantly older and less educated and at higher surgical risk underwent transapical TAVR34 (Appendix G, Table 2). This study did not report results for post-surgical incidence of any cognitive-related clinical diagnosis (Appendix H, Table 2). Both groups completed a battery of neuropsychological tests before and 3 months after the procedure, with the AVR patients administered more tests and only two tests completed by both groups. Based on a study definition for clinically significant cognitive decline as being when the number of tests with decline (followup score ≥1 SD worse than baseline) exceeded the number with improvement (followup score ≥1 SD better than baseline) by at least two for the TAVR patients and at least three for the AVR patients, TAVR patients were significantly more likely to experience cognitive decline (28 percent versus 6 percent, p=0.04) (Appendix I, Table 2). With respect to individual neuropsychological test results (Appendix J, Table 2), in the TAVR patients who provided followup data (26 percent died at 3 months), there were no statistically significant differences from baseline in any test at 3 months. In the AVR group, there also were no cognitive tests that were impaired at 3 months compared to baseline. Due to the substantial differences in patient populations, outcome measures and followup, direct comparisons of cognitive outcomes between these two treatment groups were subject to considerable bias, as a consequence of which SOE for between-group comparisons was graded as insufficient. Within study group comparisons showed small to moderate differences in neuropsychological test results between baseline and 3 months, none of which were statistically significant, though results were limited by small sample sizes.

Of note, we identified one eligible RCT that compared aortic valve replacement performed under hypothermic conditions versus aortic valve replacement performed under normothermic conditions.51 These results are presented under Key Question 2.

#### Ablation for Atrial Fibrillation

We identified no eligible study that compared either surgical or transcatheter ablation for atrial fibrillation versus any comparison group in older adults and reported cognitive outcomes.

#### Combined Cardiovascular Procedures

##### CABG Versus Cardiac Valve Replacement With or Without CABG

We identified one study that compared a combination of any the above cardiovascular procedures with a control group and reported cognitive outcomes. This was a prospective cohort study that compared participants who underwent CABG alone versus a group that included participants who underwent either surgical aortic or mitral valve replacement alone or surgical valve replacement in combination with CABG (n=109 participants) (Appendix G, Tables 1 and 2).48 This study did not report results for post-surgical incidence of any cognitive-related clinical diagnosis (Appendix H, Tables 1 and 2) or incident “cognitive impairment” as defined by a composite of neuropsychological tests (Appendix I, Tables 1 and 2). In the 68 percent of enrollees reporting results 6 months after surgery, there was no statistically significant between-group difference in the proportion of participants rated as having a deficit for 13 of 14 individual neuropsychological tests (Appendix J, Tables 1 and 2). SOE for this between treatment comparison was graded insufficient.

## Key Question 2

In older adults who undergo selected cardiovascular procedures, are associated risks for adverse post-procedural cognitive outcomes affected by procedural and peri-procedural stroke or TIA and other procedural characteristics (e.g., alternative procedures for the same indication, such as surgical versus catheter-based/stenting; anesthesia type; adjunctive neuroprotective treatments)?

### Key Findings

#### Overview

- Because strokes and TIAs were uncommon in eligible studies and risk for these events did not appear different between treatment groups, we could not determine whether risk for adverse intermediate or long-term cognitive outcomes in older adults following these cardiovascular procedures is affected by procedural and peri-procedural stroke or TIA.
- We found low SOE that intermediate and long-term cognitive outcomes are not significantly different between older adults assigned to on versus off-pump CABG.
- We found mostly low to moderate strength evidence that intermediate and long-term cognitive outcomes are not significantly different between individuals assigned to hypothermic versus normothermic CABG, and insufficient strength evidence for no difference between hypothermic versus normothermic AVR surgery.
- We found no evidence from eligible studies enrolling older adults whether procedure characteristics modify the association between carotid revascularization or ablation for atrial fibrillation and intermediate and long-term cognitive outcomes.

### Association of Incident Stroke/TIA with Cognitive Outcomes

- Procedural/peri-procedural stroke and TIA were uncommon in eligible studies of older adults (i.e., one or fewer in each treatment group in most of the 10 coronary and carotid revascularization studies that reported strokes and the four that reported TIAs) and incidence was not statistically significantly different between treatment groups. Also taking into account findings from this review that risk for intermediate and long-term cognitive outcomes didn’t appear to differ between cardiovascular procedure treatment groups, we could not determine from eligible studies whether strokes and TIAs impact risk for these cognitive outcomes.

#### Effect of Other Procedural Characteristics on Cognitive Outcomes after Coronary Artery Revascularization

- Low SOE from five RCTs that compared on versus off-pump CABG in older adults and reported no statistically significant differences between treatment groups in either risk of incident “cognitive impairment” defined from a composite of neuropsychological tests or in individual neuropsychological test results or global cognitive screening tests.
- Insufficient SOE from one prospective cohort study that compared on versus off-pump CABG in older adults and reported no statistically significant difference between treatment groups in incident “cognitive impairment” defined from a composite of neuropsychological tests or in 22 of 24 individual neuropsychological tests (2 of 24 individual tests favored the off-pump group).31, 32, 38
- Low SOE from three RCTs that compared hypothermic versus normothermic CABG in older adults and reported no statistically significant differences between treatment groups in risk of incident “cognitive impairment” defined from a composite of neuropsychological tests and low to moderate SOE that treatment groups did not differ in change from baseline or in absolute levels at followup in individual neuropsychological test results.
- Low SOE from one RCT that, when compared to older adults randomized to on-pump CABG with conventional extracorporeal bypass (CECC), those assigned to on-pump CABG with minimal extracorporeal bypass (MECC) had a significantly lower risk of incident “cognitive impairment” defined from a composite of neuropsychological tests (21 percent for MECC versus 61 percent for CECC; RR, 0.34 [95 percent CI, 0.16 to 0.73]). Low SOE that participants in the MECC group performed statistically significantly better than those assigned to CECC in six of seven neuropsychological tests reported.40
- Insufficient SOE from each of six additional RCTs that compared different versions of CABG in older adults and reported no statistically significant between-group differences in either risk of incident “cognitive impairment” defined from a composite of neuropsychological tests, but a mix of insufficient to low SOE for no difference between these different versions of CABG in any individual neuropsychological test results or global cognitive screening tests.

#### Effect of Other Procedural Characteristics on Cognitive Outcomes after Carotid Artery Revascularization

- No eligible RCT, CCT or prospective cohort study enrolled older adults undergoing any method of carotid artery revascularization and compared intermediate or long-term cognitive outcomes between those randomized with respect to another procedural characteristic (e.g., anesthetic regimen) or reported stratified results as a function of this procedural characteristic.

#### Effect of Other Procedural Characteristics on Cognitive Outcomes after Cardiac Valve Replacement

- Insufficient SOE from one RCT that compared surgical AVR under hypothermic conditions versus AVR under normothermic conditions in older adults and reported no statistically significant between-group differences in MMSE or Trail Making A tests at up to 4 months.51
- No eligible RCT, CCT or prospective cohort study enrolled older adults undergoing any method of cardiac valve replacement/repair and compared intermediate or long-term cognitive outcomes between those randomized with respect to another procedure characteristic (e.g., anesthetic regimen) or reported stratified results as a function of this procedure characteristic.

#### Effect of Other Procedural Characteristics on Cognitive Outcomes after Ablation for Atrial Fibrillation

- No eligible RCT, CCT or prospective cohort study enrolled older adults undergoing ablation for atrial fibrillation and compared intermediate or long-term cognitive outcomes between those randomized with respect to another procedure characteristic (e.g., anesthetic regimen) or reported stratified results as a function of this procedure characteristic.

Table 2 Summary of evidence on effect of procedure characteristics on association of selected cardiovascular procedures with intermediate and long-term cognitive outcomes in older adults (KQ 2)

Interventions, Studies (Study Quality) | Cognitive Outcomes | Strength of Evidence^*^
Coronary Artery Revascularization^†^
On vs. Off-Pump CABG 5 RCTs, n= up to 2349 (3 with moderate risk of bias, 2 with unclear risk of bias);29, 33, 36, 37, 39 and 1 prospective, observational study, n=227 (high risk of bias)31 | Clinically diagnosed: No results reported. Individual neuropsychological (NP) tests: No statistically significant difference between treatment groups (n=6 studies) in any absolute followup test score except in 1 of 16 measures in 1 RCT, and in 2 of 24 measures in 1 prospective cohort study. Among all studies, no statistically significant differences between treatment groups in mean change from baseline in selected NP tests,^‡^ except for in 2 measures in only 1 RCT (Trail Making B and Verbal Fluency).39 Composite neuropsychological test cognitive impairment (NPCI): No statistically significant difference between treatment groups in 4 RCTs (n=320). | Clinical: Insufficient Individual NP Tests: Low (RCTs), Insufficient (prospective observational study) Composite NPCI: Low (RCTs), Insufficient (prospective observational study)
Hypothermic vs. Normothermic CABG 3 RCTs, n=610 (moderate risk of bias)30, 37, 41, 42 | Clinically diagnosed: No results reported. Individual NP tests: No statistically significant difference between treatment groups (n=3 trials) except in 1 of 17 measures in 1 trial. No statistically significant differences between treatment groups when comparing mean change from baseline in selected NP tests.^‡^ Composite NPCI: No statistically significant difference between treatment groups. | Clinical: Insufficient Individual NP Tests: Moderate for 3 domains, Low for 2 domains, and Insufficient for 1 domain Composite NPCI: Low
Minimal vs. Conventional Extracorporeal (on-pump) CABG 1 RCT, n=64 (moderate risk of bias)40 | Clinically diagnosed: No results reported. Individual NP tests: Statistically significantly better performance in 6 of 7 administered NP tests at 3 months, including those addressing attention, executive, memory, visual/spatial, and psychomotor domains. Composite NPCI: Reduced risk (21 vs. 61%; RR, 0.34 [CI, 0.16 to 0.73]) | Clinical: Insufficient Individual NP Tests: Low for all domains except Insufficient for language Composite NPCI: Low
Carotid Artery Revascularization
No eligible studies
Cardiac Valve Replacement/Repair
Hypothermic vs. Normothermic AVR 1 RCT, n=60 (unclear risk of bias)51 | Clinical cognitive outcomes: No results reported. Individual NP tests: No statistically significant difference between treatment groups in both tests administered (MMSE, Trail Making A) at up to 4 months. Composite NPCI: No results reported. | Clinical: Insufficient Individual NP Tests: Insufficient Composite NPCI: Insufficient
Ablation for Atrial Fibrillation
No eligible studies

Abbreviations: AVR = surgical aortic valve replacement; CABG = coronary artery bypass grafting; CI = confidence intervals; KQ = Key Question; MMSE = Mini-Mental State Exam; NP = neuropsychological; NPCI = cognitive impairment as defined from a composite of neuropsychological test results; RCT = randomized controlled trial; RR = risk ratio; SOE = strength of evidence.

* Examples when evidence is available, but SOE may be graded as insufficient include when there is an unacceptably high risk of bias, or there is a major inconsistency that cannot be explained (e.g., 2 studies with the same risk of bias with opposite results and no clear explanation for the discrepancy). In addition, SOE may be graded as insufficient when data are too imprecise. This may be the case when the 95% CI is so wide that it cannot exclude either a clinically significant benefit or harm (e.g. lower CI bound <0.5 and upper CI bound >2).

† Six additional RCTs that each compared different versions of CABG, with no common comparison between the 6 trials, reported no statistically significant difference between treatment group differences in either risk of NPCI or in any individual neuropsychological test result.

‡ Selected NP tests included Trail Making A, Trail Making B, Rey Auditory Verbal Learning Test, Grooved Pegboard, and Verbal Fluency. Number of selected NP tests implemented varied between studies and sometimes between intervention groups.

### Detailed Findings

#### Impact of Stroke/TIA on Post-Procedural Cognitive Outcomes

We could not determine from available data whether risk for adverse intermediate or long-term cognitive outcomes following coronary or carotid artery revascularization, cardiac valve replacement/repair, and/or ablation for atrial fibrillation in older adults is impacted by procedural and peri-procedural stroke or TIA. This was because within eligible studies strokes and TIAs after CV procedures were uncommon, risk for strokes and TIAs didn’t appear to differ between treatment groups, and risk for post-procedural cognitive outcomes also didn’t appear to differ between treatment groups.

Among 21 eligible studies, 12 reported data on strokes and four on TIAs occurring during or after the cardiovascular procedure (Appendix K, Tables 1–3). In the studies that reported these events, occurrence was infrequent and was not statistically significantly different between treatment groups. All treatment groups had one or fewer strokes in six studies,29, 34, 36, 39, 40, 51 while in a another study stroke incidence was reported to be zero in patients treated with CEA but was not reported for the cholecystectomy control group.50 Stroke incidence was ≤4 percent and not statistically significantly different between treatment groups in four additional studies.7, 33, 38, 44 Last, stroke rate was not reported but was stated to be not significantly different between CEA and CAS in one trial,49 and the apparently lower risk of stroke in one trial that randomized 106 patients undergoing CABG to candesartan versus placebo was not statistically significant (4.7 percent versus 11.4 percent; RR, 0.41 [95% CI, 0.08 to 2.00]).47 For TIAs, all treatment groups had no TIA in two studies;39, 40 TIA incidence was ≤4 percent and not significantly different between treatment groups in 1 study;38 and TIA incidence was 2 percent in patients treated with CEA but was not reported for the cholecystectomy control group in an additional study.50

### Impact of Procedure Characteristics on Cognitive Outcomes

#### Coronary Artery Revascularization

Fourteen RCTs enrolled older adults undergoing CABG and randomized them with respect to one aspect of the CABG procedure (e.g., on versus off-pump, surgery under hypothermic conditions versus under normothermic conditions, comparison between different anesthetic agents or doses, or other) and reported cognitive outcomes. However, none reported cognitive-related clinical diagnoses. For the outcomes of incident cognitive impairment as defined by a composite of individual neuropsychological tests and of the individual neuropsychological tests, almost all of the limited available data suggested that there were no cognitive differences between any of the different versions of CABG compared, including on versus off-pump CABG, CABG under hypothermic conditions versus under normothermic conditions, CABG performed under hyperbaric oxygen conditions versus under atmospheric oxygen conditions, CABG using fentanyl versus propofol, CABG using high versus low dose fentanyl, CABG using cell saver versus using cardiotomy suction, CABG with high versus low mean arterial blood pressure maintained during cardiopulmonary bypass, and CABG with preoperative angiotensin-receptor blocker treatment versus CABG with pre-operative placebo. The one possible exception came from one small RCT in which older adults randomized to on-pump CABG with minimal extracorporeal bypass performed statistically significantly better on all but one individual neuropsychological test and were less likely to have incident cognitive impairment than those assigned to CABG with conventional extracorporeal bypass.

##### CABG: On- Versus Off-Pump

We identified five RCTs33, 35–37, 39 and one observational study31, 32, 38 that compared CABG performed on-pump versus off-pump and reported cognitive outcomes (Appendix G, Table 1). None of the six studies reported post-CABG incidence of clinical dementia, mild cognitive impairment or any other cognitive-related clinical diagnosis (Appendix H, Table 1). All five RCTs reported risk of incident cognitive impairment defined as a composite of individual neuropsychological tests at 3 to 12 months after surgery, and none reported a statistically significant difference in risk between treatment groups (Appendix I, Table 1). There also were no statistically significant differences between treatment groups in change from baseline or in absolute test score at followup for any individual neuropsychological test in any trial except for in one of 16 measures in one trial that favored the off-pump group (Appendix J, Table 1).39 SOE for these results was graded low.

The prospective cohort study did not report results for incidence of any cognitive-related clinical diagnosis or for any definition of incident cognitive impairment (Appendix H, Table 1; Appendix I, Table 1). There also were no statistically significant differences between treatment groups in change from baseline for any individual neuropsychological test. Within treatment groups, at 12 months memory was statistically significantly improved in both groups, while Trails A and Grooved Pegboard tests were improved only in the on-pump group. At 6 years, by which time there was an additional 20 to 25 percent loss to followup, there were no statistically significant differences from baseline in any neuropsychological test or global cognitive screening test. (Appendix M, Tables 1, 5, 8, 11 and 14). SOE for all between-group outcome comparisons from this cohort study was graded insufficient.

##### CABG: Hypothermic Versus Normothermic

We identified three RCTs that compared CABG performed under hypothermic conditions versus CABG under normothermic conditions in older adults and reported cognitive outcomes,37, 41, 42 one of which compared hypothermic on-pump versus normothermic off-pump CABG (Appendix G, Table 1).37

None of the three trials reported post-CABG incidence of clinical dementia, mild cognitive impairment or any other cognitive-related clinical diagnosis (Appendix H, Table 1). Though all three studies reported outcomes for incident cognitive impairment defined as post-procedural declines/deficits in a study-specific composite of individual neuropsychological tests, there was no statistically significant difference between treatment groups in these outcomes at any time point between 3 months37, 41 and 5 years30 in any of these trials (Appendix I, Table 1). SOE for these results was low.

As for individual neuropsychological test results, compared to participants randomized to normothermic conditions, those assigned hypothermic conditions had greater improvement at 3 months versus baseline on the WAIS-R Digit Span backwards (0.5 versus −0.3; effect size, 0.44 [95% CI, 0.18 to 0.70]) in one study (Appendix J, Table 1).41 However, there were no statistically significant between-treatment group differences in mean scores 12 months after surgery,37 or in change between pre-CABG levels and results 3 months to 5 years after surgery30, 41 in any other individual neuropsychological measure reported. SOE for these results mostly ranged between low and moderate.

##### CABG: Anesthetic Regimens

We identified two RCTs that compared cognitive outcomes between patients who underwent CABG performed using one anesthetic regimen versus CABG performed using a different anesthetic regimen (Appendix G, Table 1). One trial reported cognitive outcomes up to 6 months post-procedure between one group randomized to fentanyl and a second group assigned propofol (n=180).7 A second trial compared cognitive outcomes up to 12 months post-CABG between groups that received high versus low dose fentanyl, respectively (n=350).44 Neither study reported outcomes for any cognitive-related clinical diagnosis (Appendix H, Table 1); and both reported no statistically significant difference between treatment groups in risk of incident cognitive impairment as defined by a composite of individual neuropsychological tests (SOE insufficient) or in any individual neuropsychological test reported (mostly low SOE) (Appendix I, Table 1).

##### CABG: Miscellaneous Procedure Methods

Five other RCTs each compared one approach to CABG versus another, respectively performing CABG under hyperbaric oxygen conditions versus under atmospheric oxygen conditions (n=64),43 using cell saver versus using cardiotomy suction (n=226),45 maintaining high versus low mean arterial blood pressure during cardiopulmonary bypass (n=248),46 using preoperative angiotensin-receptor blocker treatment versus pre-operative placebo (n=106).47, and on-pump using minimal versus conventional extracorporeal bypass (MECC versus CECC) (n=64) (Appendix G, Table 1).40

None of these five trials reported post-CABG incidence of clinical dementia, mild cognitive impairment, or any other cognitive-related clinical diagnosis (Appendix H, Table 1).

Four of the five trials reported results for incident cognitive impairment defined by a study-specific composite of neuropsychological tests and for several individual neuropsychological tests (Appendix I, Table 1; Appendix J, Table 1).40, 43, 45, 46 Of these, three reported no statistically significant difference between treatment groups in any of these outcomes.43, 45, 46 SOE in these studies was low for several neuropsychological tests/domains in the cell saver versus suction and high versus low blood pressure trials, but otherwise was graded insufficient.

By comparison, participants randomized to MECC scored statistically significantly better than those assigned to CECC on six of seven individual neuropsychological tests.40 Further, participants randomized to MECC were significantly less likely than those assigned to CECC to have incident cognitive impairment (20.7 percent versus 61.3 percent; RR, 0.34 [95% CI, 0.16 to 0.73]). Because the criterion for incident impairment was loose (decline by ≥1 standard deviation in at least 1 of 7 neuropsychological tests) and there were few total events, the clinical relevance of this result is unclear. SOE for this treatment comparison was rated low.

#### Carotid Artery Revascularization

We identified no study that enrolled older participants undergoing carotid artery revascularization and compared cognitive outcomes between those randomized with respect to another procedure characteristic (e.g., anesthetic regimen) or that reported stratified results as a function of this procedure characteristic.

##### Cardiac Valve Replacement

We identified one eligible RCT that compared aortic valve replacement performed under hypothermic conditions versus aortic valve replacement performed under normothermic conditions in older adults (n=60 participants) (Appendix G, Table 2).51 This study did not report results for post-surgical incidence of any cognitive-related clinical diagnosis or incident cognitive impairment as defined by a composite of neuropsychological tests (Appendix H, Table 2; Appendix I, Table 2). Authors reported only that there were no between group differences in MMSE or the Trail Making A test for up to 4 months after surgery, but provided no analyzable data (Appendix J, Table 2). SOE for this treatment comparison was graded insufficient.

We identified no other eligible study that enrolled older adults undergoing cardiac valve replacement/repair and compared cognitive outcomes between those randomized with respect to another procedure characteristic (e.g., anesthetic regimen) or that reported stratified results as a function of this procedure characteristic.

##### Ablation for Atrial Fibrillation

We identified no eligible study that enrolled older adults undergoing ablation for atrial fibrillation and compared cognitive outcomes between those randomized with respect to another procedure characteristic (e.g., anesthetic regimen) or that reported stratified results as a function of this procedure characteristic.

## Key Question 3

In older adults who undergo selected cardiovascular procedures, are associated risks for adverse post-procedural cognitive outcomes affected by patient characteristics? (e.g., age; baseline cognitive function; past stroke or TIA, baseline CVD severity; hypertension; diabetes; depression)

### Key Findings

- We found no evidence from eligible studies addressing whether age, baseline cognitive function, past stroke or TIA, baseline CVD severity, hypertension, diabetes, or depression modify the association between any of these cardiovascular procedures and intermediate or long-term cognitive outcomes in older adults.
- No study reported risks for cognitive outcomes after cardiovascular procedures compared to risks in a control group (e.g., alternative cardiovascular procedure, medical management) as a function of patient characteristics, either as reported within specific study subgroups or in analyses adjusted for specific patient characteristics.
- Date were insufficient to perform meta-regression analyses to evaluate whether any between study differences in the association of cardiovascular procedures with cognitive outcomes relative to control differed as a function of between-study differences in selected patient characteristics.
  - Limitations in the available data that impeded meta-regression included there being little between-study variability in participant characteristics. For example, the mean age in nearly all studies was 65 to 69 years; with the exception of slowing on some timed tests, participants’ baseline cognitive function appeared intact; there were very few patients with prior stroke or TIA (other than in studies involving carotid revascularization); there was limited reporting of certain patient covariates (e.g., depression); and few treatment comparisons were evaluated by the same cognitive measures reported in the same way in more than one study.