# Methods

## Protocol Development

We followed a formal protocol developed with AHRQ and CMS input (Appendix A).

## Data Sources

We searched the MEDLINE^®^, Cochrane Central register of controlled trials (CENTRAL) and Scopus bibliographic databases. An MLIS research librarian experienced in systematic review search methodology and not involved in the project helped refine our bibliographic literature search strategy. To identify additional completed studies, we also reviewed reference lists of included studies, previous systematic and narrative reviews, and ClinicalTrials.gov. We restricted inclusion to studies published from 1990 through July 2014 to limit the review to studies of cognitive outcomes after cardiovascular procedures that reasonably reflect current clinical practice. Appendix B contains the full search strategy.

## Study Inclusion Criteria

### Study Design

- We restricted the review to randomized controlled trials (RCTs), nonrandomized comparative trials, and appropriately controlled prospective observational cohort studies. We selected these study designs to minimize comparison group differences other than the cardiovascular procedure, to increase consistency in how the cardiovascular procedures evaluated within each individual study were performed, and ensure that post-procedural cognitive outcomes were assessed prospectively.

### Population

- Studies must have included participants who were exclusively or predominately aged ≥65 years (either all participants were ≥65, study mean or median age was ≥65 years, or data were reported from a subgroup of at least ten patients aged ≥65 years).
- We included studies with at least ten participants for each treatment arm for RCTs and at least 50 participants in each arm for other eligible study designs.

### Interventions

Participants in at least one study arm must have undergone at least one of the following cardiovascular procedures:

- Coronary artery revascularization (e.g., CABG, percutaneous coronary intervention [PCI]);
- Carotid artery revascularization (e.g., CEA, CAS, carotid angioplasty);
- Cardiac valve replacement/repair (e.g., surgical or transcatheter, aortic or mitral);
- Ablation for atrial fibrillation (e.g., surgical, transcatheter).

### Controls

- Studies must have included a control group whose participants did not undergo the cardiovascular procedure of interest or who underwent a modified version of the procedure.

### Outcomes

Because the focus of this review was on intermediate-term (3 to 12 months) and long-term (>12 months) cognitive outcomes after cardiovascular procedures, studies must have reported at least one cognitive outcome at least 3 months after the procedure.

Studies which reported only shorter-term followup were excluded to limit the potentially transient impact of factors other than the cardiovascular procedure on reported cognitive outcomes (e.g., pain, anesthesia, medications, sleep deprivation, and other unrelated hospital-related illness). Our interest in looking at cognitive outcomes measured at >12 months was to assess whether earlier onset cognitive effects persist long-term.

Given the uncertainty about whether and in what manner these cardiovascular procedures impact cognitive outcomes, we did not believe it made sense to prejudge which cognitive domains to consider while excluding others from our review. Therefore, we considered studies eligible if they assessed any measured (i.e. not self-reported) cognitive outcome, but particularly measures focusing on attention, memory, language, executive function, psychomotor speed, or visuospatial function, or a global cognitive screen (e.g. Mini-Mental State Exam [MMSE]).

To account for the possible effect of between-group differences in pre-procedural cognitive function on between-group differences in post-procedural cognitive function, all non-RCTs must have performed pre-procedural neuropsychological assessments.

#### Primary Outcomes

- Clinically diagnosed cognitive impairment based on: (1) the presence of symptoms and/or functional impairment, and (2) abnormal neuropsychological testing based on performance on multiple neuropsychological tests that assessed multiple cognitive domains.

#### Secondary Outcomes

- Clinically meaningful change in neuropsychological test results regardless of whether symptoms or functional impairment were documented. This could involve one or more neuropsychological tests that addressed one or more cognitive domains and/or brief global cognitive screening measures, though we included any objectively tested cognitive outcomes studies reported.
- Continuous measure/change in one or more of the above neuropsychological or brief global cognitive screening test results.

### Setting

- Studies were eligible regardless of whether the cardiovascular procedure took place in the inpatient or outpatient setting. However, studies in which intermediate- and long-term post-procedure cognitive assessments were available only from within the inpatient setting were excluded. The purpose for this exclusion is the concern that patients who remain inpatients >3 months after their procedure likely have experienced medical complications unrelated to their procedure that could impact their cognitive function.

### Language

The full text of eligible studies must have been published in English.

## Triage

First, two independent investigators reviewed titles and abstracts and categorized them as ‘include,’ ‘exclude,’ or, when a determination could not be made based on title and abstract alone, as ‘full text review needed.’ Differences in triage decisions between the two investigators were resolved by consensus discussion, involving the lead investigator as necessary.

Two independent investigators then reviewed the full texts of all studies rated ‘include’ or ‘full text review needed’ to determine final eligibility. Any differences in their eligibility ratings were resolved by consensus discussion, involving the lead investigator as necessary. Reasons for exclusion of studies during the full text screening stage were recorded (Appendix C).

## Data Extraction

For each eligible study, 1 study investigator extracted data onto pre-tested extraction forms/evidence tables. A second investigator double checked extracted data for accuracy. Differences between the two reviewers were resolved by consensus discussion, involving the lead investigator as necessary.

Extracted data fields included author; publication year; study design; cardiovascular procedure and control regimens; anesthesia type and duration; adjunctive treatments intended to lower risk of adverse cognitive outcomes; sample size; participant inclusion and exclusion criteria; participant baseline age; prevalence of hypertension, diabetes, stroke/cerebrovascular disease, and depression; type(s) of pre-procedural neuropsychological assessment (e.g., specific brief global cognitive screening measures and specific cognitive domains tested); N, mean and SD for each reported pre-procedural neuropsychological test score; incidence of procedural and peri-procedural stroke and/or TIA; timing, definition, and event rates/results of clinically diagnosed post-procedural cognitive outcomes and post-procedural neuropsychological tests; and post-procedural minus pre-procedural changes in neuropsychological test scores (i.e. mean change from baseline).

Authors of studies otherwise meeting eligibility criteria, but not reporting mean and SD for pre- and post-procedural neuropsychological testing were contacted in an effort to obtain this information. When these results or post-procedural minus pre-procedural changes were not directly reported by the study, but could be calculated from available data, we performed these calculations, particularly for the most commonly performed neuropsychological tests (i.e. Trail Making A, Trail Making B, Rey Auditory Verbal Learning Test, Grooved Pegboard, Verbal Fluency, Digit Symbol, Digit Span Forward, Digit Span Backward, Boston Naming Test, Vocabulary [WAIS], and Block Design). For each study, post-procedural cognitive assessments were categorized into those measured at 3 to 12 months (intermediate-term) and those measured >12 months after the procedure (long-term), with only the latest assessment of each cognitive measure within a time period extracted.

## Risk of Bias Assessments for Individual Studies

We evaluated risk of bias in individual studies according to recommendations from the Cochrane Handbook for Systematic Reviews of Interventions.21 Following categorization of studies according to their design as either interventional (RCTs, nonrandomized controlled clinical trials [i.e. controlled clinical trials or CCTs]) or prospective observational cohort studies, two investigators reviewed each study for risk of bias for the neuropsychological outcomes, collectively including both the individual neuropsychological test results and the composite “cognitive impairment” outcomes. Because no study reported clinically diagnosed cognitive outcomes (e.g., Alzheimer’s or vascular dementia, mild cognitive impairment), risk of bias could not be assessed for these outcomes.

For interventional studies, we evaluated risk of bias using the following criteria from the Cochrane Risk of Bias tool22: (1) random allocation of the subjects to the treatment groups; (2) adequacy of allocation concealment23; (3) masking of the outcome assessment (participant, investigator, and/or outcome assessor); (4) use of intention-to-treat principles (i.e., inclusion of all randomized participants in their originally assigned group in outcomes analyses); and (5) selective reporting of prespecified outcomes. Generally, we assumed a low risk of bias when individual interventional studies met all quality criteria, a moderate risk of bias if at least one of the quality criteria was not met, and a high risk of bias if multiple quality criteria were not met.24 However, we concluded an unclear risk of bias when at least 2 individual criteria were rated unclear and no more than one criterion was rated high-risk.

For prospective cohort studies, we assessed risk of bias using the following criteria from the AHRQ Methods Guide:24 (1) similarity of groups in important prognostic variables; (2) masking of the outcome assessment (outcome assessor); (3) attrition bias (if overall or differential dropout/loss to followup or exclusions were a concern, missing data appropriately handled); and (4) selective reporting of prespecified outcomes. Generally, we assumed a low risk of bias when individual prospective observational cohort studies met all quality criteria, a moderate risk of bias if at least one of the quality criteria was not met, and a high risk of bias if multiple quality criteria were not met.24 We concluded an unclear risk of bias when at least 2 individual criteria were rated unclear and no more than one criterion was rated high-risk.

Differences in risk of bias assessments between the two investigators were resolved by consensus discussion, involving the lead investigator as necessary.

## Data Synthesis

Study results were organized by cardiovascular procedure category, study design, and then by duration between procedure and followup cognitive assessment (i.e., intermediate-term [3 to 12 months] and long-term [>1 year]).

To pool descriptive data on participant characteristics across multiple studies, we calculated weighted means by multiplying each variable (e.g. age) by its corresponding study sample size (n), and then dividing the sum of the products by the sum of the study sample sizes (N). Therefore, if the study had a larger sample size, it contributed more to the calculated mean of the variable in question.

We used Review Manager (RevMan) version 5.2 software to estimate relative risks and 95 percent confidence intervals for the incidence of dichotomous outcomes and standardized mean differences (effect sizes) and 95 percent confidence intervals for continuous outcomes (e.g., for mean between-group difference in followup scores).25 The effect sizes were interpreted using the definition from Cohen of small (≥0.2 to <0.5), medium (≥0.5 to <0.8), and large (≥0.8).26 Where possible, outcome measures were quantitatively summarized. However, this was infrequently possible because few studies had clinically comparable patient populations, cardiovascular procedure and comparison groups and reported the same cognitive outcomes in a comparable way.

To investigate the possible effect of procedure-related factors on the association between cardiovascular procedures and adverse cognitive outcomes, we had planned to consider the following subgroup analyses: incidence of procedural or peri-procedural stroke or TIA; different procedures for the same clinical indication, such as surgical versus catheter-based/stenting; anesthesia type and duration; procedure duration; and use of adjunctive neuroprotective treatments. However, available data were insufficient to allow these analyses.

To investigate the possible effect of patient characteristics on the association between cardiovascular procedures and adverse cognitive outcomes, we had planned to consider the following subgroup analyses: age; baseline cognitive function; past stroke or TIA, baseline CVD severity; hypertension; diabetes; and depression. Then, if these subgroup analyses were not possible, we planned to perform random-effects inverse weighted meta-regression on these patient characteristics. However, available data were insufficient to allow these analyses.

## Grading Strength of Evidence for Individual Outcomes

We graded the overall strength of evidence (SOE) for the studies in this review using methods developed by the AHRQ and the Effective Health Care Program.27

Within each cardiovascular procedure and control comparison examined, we evaluated SOE for RCTs separately from that for prospective cohort studies. Within each study design category, we rated SOE separately for clinically diagnosed cognitive outcomes (e.g., dementia, mild cognitive impairment), each brief global cognitive screening test, and each of the following cognitive domains (attention, memory, language, executive, visual-spatial functioning, and psychomotor speed). For each cardiovascular procedure and control comparison, we then considered the results from the different study designs together and reported a single SOE for each cognitive outcome. SOE ratings were performed independently by two senior reviewers, with differences between the two investigators resolved by consensus discussion, involving the lead investigator as necessary.

In each case, SOE was evaluated based on the following domains: (1) risk of bias (or internal validity); (2) directness; (3) consistency; (4) precision; and, when appropriate, (5) reporting bias. Study limitations were rated as low, medium or high based on the study design and risk of bias of individual studies. Directness was rated as direct or indirect based on whether evidence provided a single, direct link between intervention and outcomes. Consistency was rated as consistent, inconsistent, or unknown (e.g., single study) based on the degree to which included studies appeared to have the same direction or magnitude of effect. Precision was rated as precise, imprecise, or unknown based on the degree of uncertainty surrounding the effect estimate that was attributable to insufficient sample size and/or the number of outcome events. An imprecise estimate would be one in which the effect estimate was wide enough to include clinically distinct conclusions. For example, in a comparison in which results suggested no statistically significant difference between treatment groups (i.e. effect size 95% confidence intervals straddled zero), results could not exclude a moderate or larger difference between groups in either direction (upper bound of effect size CI ≥0.5 or lower bound of CI ≤−0.5). Reporting bias was rated as suspected or undetected based on detection of publication, outcome and/or selective analysis reporting bias. Other factors that were considered in assessing SOE included dose-response relationship, presence of confounders, and strength of association. Based on these factors, the overall SOE was rated qualitatively as:

- High: We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable. An overall rating of high SOE would imply that the included studies were RCTs with a low risk of bias, with consistent, direct, and precise domains.
- Moderate: We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
- Low: We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient: We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding judgment.

Detailed SOE ratings are reported in Appendix L.

## Assessing Applicability

Specific study characteristics that may affect applicability were noted on evidence tables. These characteristics may include non-U.S. settings; narrow participant eligibility criteria; participant age, gender, race, or educational level; participant baseline cognitive function and other comorbid characteristics; and use of cognitive assessments not typically used in current U.S. clinical practice.28

## Role of the Funding Source

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the AHRQ. AHRQ assigned this report to the Minnesota Evidence-based Practice Center (EPC) (Contract Number: 290-2007-100641). The scope and Key Questions were developed with input from the AHRQ and the CMS.