# Introduction

## Background

Concern about the possible association between cardiovascular procedures and subsequent cognitive outcomes is long standing. Particularly for coronary artery bypass grafting (CABG), and to a lesser extent for other procedures such as carotid endarterectomy (CEA), cardiac valve replacement, and catheter ablation for atrial fibrillation, these concerns have stimulated investigations to try to protect against adverse cognitive outcomes and have raised questions about the relative benefits and harms of these procedures versus alternatives and whether targeting interventions based on patient characteristics such as age and baseline cognitive function could improve patient cognitive outcomes.

Many early studies reported a high but variable incidence of post-CABG cognitive impairment. Etiological factors were thought to include anesthesia, cardiopulmonary bypass, hypoperfusion and embolic stroke, among others. However, these studies may have overestimated the incidence of persistent cognitive impairment attributable to CABG. Many studies did not adequately account for pre-existing cognitive impairment, transient post-procedural cognitive impairment, post-procedural cognitive declines due to underlying systemic disease, and/or test imprecision and practice effects from early and repeated cognitive testing.1

More recent studies more consistently performed pre-procedural cognitive assessments, compared results from patients receiving CABG with those from a control group, and used a battery of neuropsychological tests recommended by one group for cognitive assessment of these patients.2 A 2012 systematic review of 29 studies that included a mix of older and newer studies reported that psychomotor speed was slightly but significantly impaired for <2 weeks after CABG, but that psychomotor speed, memory and executive functioning were slightly but significantly improved compared to baseline by 3 months.3 In the few studies reporting, these small improvements appeared sustained at 6 to 12 months. That review did not report other neuropsychological domains and did not indicate whether neuropsychological test abnormalities were associated with functional impairment. Further, one-third of included studies had only short-term (<3 months) post-procedure followup and, of the remainder, mean age was <65 years in all but four studies, limiting their relevance to the aging population that is increasingly undergoing CABG.

Although adverse post-CABG cognitive outcomes have been associated with several patient characteristics, including increased age, less education or social support, cerebrovascular or peripheral vascular disease, hypertension, diabetes, and depression,1, 4–7 studies of risk factors have not generally included control groups. While multiple reviews have reported no difference in cognitive risk between on and off-pump CABG,3, 8 less is known about the effect of other procedure-related factors on post-CABG cognitive outcomes, including both adjunctive interventions and procedural or peri-procedural stroke or transient ischemic attack (TIA).

The impact of carotid revascularization on persistent cognitive outcomes in older adults also is uncertain. Though many older CEA studies reported cognitive improvements, these studies often lacked a control group and results may have benefitted from practice effects.9, 10 Older studies reporting post-CEA cognitive declines also often had only short-term followup, making it difficult to separate out the potential transient effects of anesthesia, pain, medications, sleep deprivation, and other hospital-related illness unrelated to the CEA. Carotid artery stenting (CAS) is a less invasive, percutaneous alternative to CEA for carotid revascularization whose association with cognition has been less studied than CEA, but some studies have raised alarms by finding a higher frequency of imaging-detected microemboli with CAS than CEA.11, 12 Carotid revascularization procedures also could affect cognition by causing an acute clinical stroke or TIA, transiently altering cerebral perfusion, and from the effects of anesthesia, but also by improving cerebral circulation and lowering longer term stroke risk.13

In a 2011 systematic review, about half of studies of CEA and/or CAS reported improvement in at least one neuropsychological test and about half reported some decline or no change.14 The authors suggested that the mixed findings might be explained by variable followup times (including many <1 month), variability in the neuropsychological tests administered, and heterogeneity in patient populations and surgical management. About one-third of included studies also did not compare cognitive changes to those in a control group, a limitation in distinguishing between the effects of the procedure and those of patient characteristics and other causes of cognitive changes. In addition, many of the studies had a limited representation of older adults. Consequently, the review findings may have had limited applicability to the intermediate and long-term cognitive outcomes after carotid revascularization procedures in older adults. Authors suggested that the impact of patient and procedure factors on cognitive outcomes after CEA and CAS needed further examination.

The impact of cardiac valve replacement or repair procedures on intermediate and long-term cognitive outcomes in older adults also is unclear. Studies have consistently reported a high frequency of imaging-detected cerebral emboli, though with only a minority of these abnormalities associated with focal neurologic symptoms. For example, in one review of transcatheter aortic valve replacement (TAVR) studies, while most patients had ischemic defects identified on diffusion-weighted MRI days after the procedure, symptomatic stroke was only identified in about 3 percent of participants.15 Though cardiac valve procedures could adversely affect cognition through similar mechanisms as those proposed for CABG, cognitive outcomes after these procedures have been less frequently studied, especially beyond the short-term. Studies comparing surgical aortic valve replacement (AVR) and TAVR suggest a higher risk of cerebral emboli and stroke with TAVR, which also could lead to differences in cognitive outcomes, but these have been less consistently reported.16 Mitral valve procedures have been less studied, but limited data suggest that cognitive outcomes may differ between mitral valve replacement and repair.17 We have not identified any systematic reviews on cognitive outcomes after cardiac valve procedures, let alone one that addresses more than short-term outcomes and focuses on older adults, who may be at greatest risk for these adverse effects.

Relatively little is known about the cognitive effects of catheter ablation procedures for atrial fibrillation. Risk of periprocedural stroke is about 1 percent, but brain MRI studies have identified new ischemic lesions in 7 to 14 percent of patients overall, with substantial variability by ablation technique.18 Regarding clinical cognitive outcomes, a large administrative data study reported that patients with atrial fibrillation who underwent catheter ablation were at significantly lower risk for a dementia diagnosis at 1 and 3 years than those with atrial fibrillation who didn’t receive ablation and were at similar risk to those without atrial fibrillation.19 However, these results could have been vulnerable to misclassification and treatment selection bias. Another small study reported that predominately middle-aged individuals who underwent catheter ablation for atrial fibrillation had both more frequent ischemic lesions on post-procedural MRI and relatively more decline in cognitive performance at 3 months in verbal but not nonverbal memory compared to healthy controls.20 However, these results must be interpreted cautiously given the small number of events and the absence of between-group differences in any of the other cognitive domains tested.

## Purpose of Comparative Effectiveness Review

This systematic review aims to characterize the intermediate and long-term cognitive outcomes attributable to coronary and carotid revascularization procedures, cardiac valve replacement/repair, and ablation for atrial fibrillation, and the extent to which these associations are modified by procedural and patient characteristics and by procedure-related stroke and/or TIA. These procedures were nominated to the Agency for Healthcare Research Quality (AHRQ) for study by the project nominator, the Centers for Medicare and Medicaid Services (CMS). This review also aims to define the limitations of existing evidence, provide guidance for informed patient-provider discussions about any intermediate and long-term cognitive risks associated with these procedures, and describe the parameters of any future research studies needed to address remaining evidence gaps. Improving understanding of the duration, pattern and risk factors for cognitive outcomes attributable to these cardiovascular procedures in older adults may help guide treatment selection, matching patients to procedures to achieve the best intermediate and long-term cognitive outcomes, and guide informed pre-procedural discussions between clinicians and patients about any longer-term cognitive risks.

## Analytic Framework and Key Questions

During this project’s topic refinement, AHRQ and CMS agreed that an independent, comprehensive review of the issues introduced above and as elaborated in the following analytic framework (Figure 1) and Key Questions would provide helpful guidance to clinicians and policymakers about the risks for cognitive outcomes after selected cardiovascular procedures.

Figure 1 Analytic framework

Figure 1. This figure depicts the key question and subquestions within the context of the PICOTS described in the previous section. In general, the figure illustrates how older adults undergoing selected cardiovascular procedures may experience adverse cognitive outcomes such as incident dementia or MCI, or changes in neuropsychiatric test results. It also illustrates how the association between these cardiovascular procedures and adverse cognitive outcomes may be modified by procedure and/or patient characteristics.

### Key Question 1

In older adults who undergo selected cardiovascular procedures, what are the associated post-procedural cognitive outcomes (e.g., clinical severity; timing/duration; pattern of cognitive domain impairment)?

### Key Question 2

In older adults who undergo selected cardiovascular procedures, are associated risks for adverse post-procedural cognitive outcomes affected by procedural and peri-procedural stroke or TIA and other procedural characteristics (e.g., alternative procedures for the same indication, such as surgical versus catheter-based/stenting; anesthesia type; adjunctive neuroprotective treatments)?

### Key Question 3

In older adults who undergo selected cardiovascular procedures, are associated risks for adverse post-procedural cognitive outcomes affected by patient characteristics (e.g., age; baseline cognitive function; past stroke or TIA, baseline cardiovascular disease [CVD] severity; hypertension; diabetes; depression)?