# Discussion

## Do Selected Cardiovascular Procedures Impact Cognitive Outcomes in Older Adults?

Few eligible studies in older adults compared selected cardiovascular procedures with medical management or compared more versus less invasive cardiovascular procedures and reported intermediate and/or long-term cognitive outcomes.

Single studies of CABG versus medical management, CEA versus CAS, CEA versus carotid angioplasty, and cardiac valve replacement with or without CABG versus CABG alone each found no difference in intermediate and/or long-term cognitive outcomes between treatments. Beyond there being no statistically significant between-group differences in these cognitive outcomes, the small magnitude of both the between-group differences and the within-group change scores suggested that these findings may not be due just to low statistical power. Any intermediate to long-term cognitive differences between these treatments in older adults, if they exist, may be small. One study of AVR versus TAVR reported significantly increased incidence of intermediate-term cognitive impairment in TAVR participants, but because these results could have been biased by substantial between-group differences in cognitive risk factors and by use of different cognitive outcome measures, these results are difficult to interpret.

However, in addition to the small number of studies that were eligible, and the several treatment comparisons for which we identified no eligible studies (e.g. CABG versus PCI; PCI versus medical management; CEA, CAS or carotid angioplasty versus medical management; AVR or TAVR versus medical management; aortic or mitral valve replacement versus valve repair; ablation for atrial fibrillation versus medical management), many of the studies identified had small sample sizes, and all had at least moderate risk of bias. While SOE for the comparison of outcomes between CEA and CAS were mostly graded as low, SOE for these other treatment comparisons was uniformly considered insufficient. Additional studies could substantially change the estimates of effect of these cardiovascular procedures on cognitive outcomes in older adults.

## Is Any Association Between Selected Cardiovascular Procedures and Cognitive Outcomes in Older Adults Attributable to Procedure-Related Strokes and/or TIAs?

We could not determine from available data whether risk for adverse intermediate or long-term cognitive outcomes following coronary or carotid artery revascularization, cardiac valve replacement/repair, and/or ablation for atrial fibrillation in older adults is affected by procedural or peri-procedural stroke or TIA. This was because, within eligible studies, strokes and TIAs after these cardiovascular procedures were uncommon; risk for strokes and TIAs didn’t statistically significantly differ between treatment groups; and risk for post-procedural cognitive outcomes generally didn’t significantly differ between treatment groups. While data from eligible studies don’t suggest that procedure-related stroke or TIA cause intermediate and/or long-term cognitive impairment, statistical power concerning this association was clearly inadequate for this conclusion to be definitive. Further, given that few participants in eligible studies other than the carotid revascularization RCTs had a prior history of stroke, the low frequency of procedural and peri-procedural stroke and TIA and lack of association with cognitive outcomes after these procedures in eligible studies may not be representative of patients at higher stroke risk undergoing these procedures in the community.

## Is Any Association Between Selected Cardiovascular Procedures and Cognitive Outcomes in Older Adults Modified by Procedural Characteristics?

For all but two treatment comparisons (on versus off-pump CABG [n=6 studies], and hypothermic versus normothermic CABG [n=3 studies]), there were only single studies that addressed whether differences in how CABG was performed were associated with intermediate or long-term differences in cognitive function in older adults.

For the on versus off-pump CABG and hypothermic versus normothermic CABG comparisons, we found low and low to moderate strength evidence, respectively, that there was no difference in intermediate and/or long-term cognitive function between treatment groups. Beyond there being no statistically significant between-group differences in these cognitive outcomes, the small magnitude of both the absolute between-group differences and the within-group change scores suggested that these findings may not be due just to low statistical power, but that any intermediate to long-term cognitive differences between these treatments in older adults, if they exist, may be small.

Six additional RCTs, each comparing one version of CABG versus another (i.e. different anesthesia regimens, hyperbaric versus atmospheric oxygen, high versus low mean arterial blood pressure, preoperative candesartan versus placebo, use of cell saver versus cardiotomy suction), all found no significant difference between treatment groups in intermediate-term cognitive outcomes in older adults. Individually, each of these studies has no better than moderate risk of bias and provides insufficient to low SOE to conclude that its observed outcome accurately reflects the true effect. However, viewed together, and in the context of the negative on versus off-pump CABG, and hypothermic versus normothermic CABG studies, these results are at least suggestive that CABG procedure characteristics may have little to no effect on intermediate to long-term cognitive outcomes in older adults. Alternatively, these results could be explained by the inability of limited quality studies to identify true effects of one or more CABG procedure characteristics on these cognitive outcomes. Or, procedure characteristics don’t make a difference in intermediate to long-term cognitive outcomes in older adults because CABG itself doesn’t affect these outcomes.

But, none of these explanations may be correct if the results from a single, 3-month RCT in which older adults were randomized to minimal extracorporeal bypass versus conventional extracorporeal bypass are true.40 In this small trial (n=64), we found low SOE that risk of incident cognitive impairment was statistically significantly reduced by two-thirds and six of seven individual neuropsychological tests were better at followup in the minimal compared to the conventional bypass group. Because the criterion for incident cognitive impairment was lenient (decline by ≥1 standard deviation in at least 1 of 7 neuropsychological tests), it is likely that some individuals met this criterion due to chance. Since there were relatively few total events, the clinical relevance of this result is still unclear. A recent meta-analysis of RCTs comparing minimal versus conventional extracorporeal bypass CABG unrestricted by age reported no statistically significant reduction in neurologic events, but didn’t report cognitive outcomes specifically, and noted that available studies were generally small and limited in quality.52 A trial comparing minimal versus conventional extracorporeal bypass CABG is now enrolling participants and aims to randomize 150 participants ages 18 to 80 years, and to follow them for neurocognitive function among other outcomes for up to six months.53 Given the age entry criteria, and the absence of information about whether the study is using more rigorous cognitive outcomes, it is unclear if it will clarify whether minimal extracorporeal bypass truly improves intermediate-term cognitive outcomes in older adults undergoing CABG procedures.

Data on the potential impact of procedural characteristics on the association between cardiovascular procedures and intermediate and/or long-term cognitive outcomes was more limited for other procedures. One RCT found no statistically significant difference in cognitive outcomes at 4 months between older adults randomized to hypothermic versus normothermic AVR. However, we considered the SOE for this comparison insufficient. Wee found no evidence addressing whether the association between carotid revascularization or atrial fibrillation ablation procedures and cognitive outcomes is modified by procedural characteristics. Consequently, whether any procedural factors affect intermediate or long-term cognitive outcomes after cardiac valvular, carotid revascularization or atrial fibrillation ablation procedures in older adults is far from settled.

## Is Any Association Between Selected Cardiovascular Procedures and Cognitive Outcomes in Older Adults Modified by Patient Characteristics?

Increased age, less education or social support, cerebrovascular or peripheral vascular disease, hypertension, diabetes, and depression have been suggested as patient factors that may predict cognitive outcomes after cardiovascular procedures.1, 4–7 However, these data were derived solely from studies of CABG, many of which were uncontrolled, short-term and/or unrestricted to older adults. We sought to identify evidence about whether they predict intermediate and/or long term cognitive impairment after several different types of cardiovascular procedure in older adults.

Unfortunately, we found no evidence from eligible studies addressing whether any of these patient characteristics modify the association between coronary or carotid artery revascularization, cardiac valve replacement/repair, and/or ablation for atrial fibrillation and intermediate or long-term post-procedural cognitive outcomes in older adults. Further, because eligible studies were mostly comprised of men, had a low prevalence of stroke, and included few old-old participants, it may not have been possible to evaluate the impact of variability in these patient characteristics on intermediate and long-term post-procedural cognitive outcomes from these studies.

While older individuals, who are increasingly undergoing these cardiovascular procedures, would be expected to have a higher prevalence of baseline cognitive impairment, higher risk of cognitive decline unrelated to any cardiovascular procedures, and, potentially, greater vulnerability to cognitive decline related to cardiovascular procedures, this could not be determined from eligible studies. This is an important research gap.

## What are the Benefits and Harms of Cognitive Testing Before and After Selected Cardiovascular Procedures?

Evidence from our review does not address whether cognitive testing before and after selected cardiovascular procedures improve short-term cognitive outcomes or any noncognitive outcomes. It also does not address whether cognitive screening benefits outweigh harms in any other population (e.g., older adults not scheduled for these cardiovascular procedures or scheduled for noncardiovascular procedures, younger patients). Some of these important questions have been addressed by recommendations and guidelines by other groups.54–56

The focus of our review was to evaluate whether selected cardiovascular procedures affect intermediate and long-term cognitive outcomes in older adults, including whether this association is impacted by patient characteristics such as baseline cognitive function. A finding that baseline cognitive function predicts differences in intermediate and long-term cognitive outcomes in older adults between one or more cardiovascular procedure and their treatment alternatives could provide guidance in selecting between treatment options. However, studies eligible for this review did not provide data to inform treatment decisions in this way. Additional research will be needed to address this question, such as studies in older adults that report results stratified by or adjusted across a broad range of baseline cognitive function.

A finding that baseline cognitive function predicts intermediate and/or long-term cognitive outcomes in older adults undergoing selected cardiovascular procedures might be used to counsel patients even if it doesn’t distinguish these outcomes between different treatment alternatives. For example, patients identified with more baseline cognitive impairment might be counseled that they have an increased risk of intermediate and long-term post-procedure cognitive not caused by the procedure. Again, studies eligible for this review did not provide data to confirm this association.

In sum, we found no direct evidence about whether pre and/or post-procedural cognitive testing may lead to improvement in intermediate and long-term cognitive outcomes in older adults. Valuable future research may address whether cognitive testing before and/or after selected cardiovascular procedures impacts intermediate and long-term cognitive outcomes and other important related outcomes (e.g., patient autonomy related to capacity to consent, complications related to adherence with post-surgical instructions, quality of life, costs).

## How May Findings From This Review Inform the Provider-Patient Consent Process for Selected Cardiovascular Procedures?

Our review found limited evidence in older adults addressing whether intermediate and long-term cognitive outcomes after coronary or carotid artery revascularization or cardiac valve replacement are attributable to these procedures. We found low to insufficient strength evidence suggesting that there is no difference in intermediate-term cognitive outcomes between older adults who undergo CEA versus either of two less invasive alternatives, CAS or carotid angioplasty. We found no evidence from eligible studies about whether these cognitive outcomes are attributable to ablation for atrial fibrillation. Other than one provocative but unconfirmed study suggesting intermediate-term cognitive benefits from minimal versus conventional extracorporeal bypass CABG (low SOE), we found limited evidence that there is no significant difference in intermediate and long-term cognitive outcomes between different versions of CABG and between different methods of carotid artery revascularization. While SOE suggesting that there was no difference in longer term cognitive outcomes between on versus off-pump CABG and hypothermic versus normothermic CABG was low and moderate, respectively, SOE for for there being no difference in these cognitive outcomes between other versions of CABG ranged between insufficient and low.

Therefore, it may be appropriate for providers performing consent to inform older patients that though there is substantial uncertainty about the cognitive risk from these procedures in older adults, limited evidence (both in number of studies and study quality) suggests that intermediate and long-term cognitive risks attributable to the CABG, carotid revascularization, and AVR procedures, or to different versions of these procedures may be small. Though assessment of the risk of short-term cognitive impairment after these cardiovascular procedures was outside the scope of our review, our results suggest that if such short-term impairment occurs, there is at least limited evidence that any cognitive effects from the procedure may be transient. It may be more likely that longer lasting cognitive impairment after these cardiovascular procedures reflects cognitive impairment that was present prior to the procedure, whether or not it was fully recognized.

## Applicability

No RCT compared a cardiovascular procedure versus medical management. Only two of 17 RCTs compared different cardiovascular procedures with each other, both of which compared CEA versus a less invasive procedure for treatment of carotid stenosis (i.e., versus CAS and carotid angioplasty, respectively). Most trials were limited to individuals undergoing CABG and compared different versions of the CABG procedure. Most participants in these studies were men. By design, our review was limited to studies in which most or all participants were aged ≥65 years, but most studies appeared to include few old-old participants (e.g., aged ≥80 years). Studies appeared to enroll predominately participants with limited cognitive impairment, and, other than in the carotid artery revascularization studies, pre-procedural history of stroke was rare. Studies also reported very limited information on participant and procedure characteristics, including on race, comorbid conditions, CVD severity, and adjunctive procedures performed to try to prevent adverse cognitive outcomes.

Taking these trial characteristics into account, results from this review may have limited generalizability to the oldest patients who undergo these cardiovascular procedures in the community, to women, to patients with more substantial baseline cognitive impairment, or to those with past stroke. Further, results may not be generalizable to patients with comorbid conditions not reported (though not explicitly excluded in most cases) in eligible studies (e.g., depression).

## Future Research Recommendations

Table 3 summarizes the areas needing future research based on the gaps identified in this review.

Table 3 Future research recommendations

Research Gaps | Future Research Recommendations
General Issues
- No eligible studies reported clinically diagnosed cognitive outcomes (e.g., dementia, mild cognitive impairment) based on an assessment of symptoms, functional ability, and neuropsychological testing.; - Though many studies reported an outcome of incident cognitive impairment, defined by a study-specific combination of 1 or more individual neuropsychological tests meeting a study-specific threshold for abnormality or decline, the meaning of this outcome is unclear. There was no standard definition across studies, either in how many tests were assessed, which tests were assessed, how tests were scored, how many tests must have been abnormal, or in how abnormal was defined (e.g., decline of 20% 0.5 SD, or 1 SD). These thresholds do not appear to equate to a clinically meaningful change in these continuous neuropsychological tests. In fact, because criteria could have been met based on sometimes modest abnormalities in a small proportion of administered tests, some participants may have met criteria due solely to chance variation in test performance.; - Statistical pooling of results from different studies was impeded by between-study variability in neuropsychological testing performed, including use of different tests, use of different versions of the same test, and unclear reporting about what tests were used and how test results were derived.; - Followup duration in most studies may have been too short to evaluate long-term cognitive effects of these cardiovascular procedures.; - This review only considered intermediate (3 to 12 months) and long-term (>12 months) post-procedural cognitive outcomes. The effect of selected cardiovascular procedures on shorter-term cognitive outcomes was outside the scope of this review.; - Many studies not included in this review have examined the association between cardiovascular procedures and subsequent cognitive outcomes without reference to a control group. This may have resulted in attribution of post-procedure cognitive impairment to the procedure that was partly or completely due to patient characteristics. | - Future studies should report clinically diagnosed cognitive outcomes based on patient/informant history, formal cognitive testing and functional assessment, such as incident dementia or mild cognitive impairment, although the incidence of these outcomes may be very low.; - Future studies should use a standardized definition of incident cognitive impairment. Ideally, it would represent a clinically meaningful change in cognition from a pre-procedure baseline. It should be based on standardized scoring of a standard battery of individual neuropsychological tests sensitive to cognitive changes over time but that minimize learning effects. One possible approach would be to perform between-group statistical significance testing of continuous neuropsychological test scores (e.g. post-procedure, or change between pre- and post-procedure). Results should be adjusted for multiple comparisons along with determining whether the magnitude of any statistically significant difference exceeds a rigorous threshold.; - Studies should identify a primary neurocognitive outcome and use it to calculate a sample size sufficient to detect a clinically meaningful difference between treatment groups.; - Future studies should include control groups (e.g. alternative procedure, medical management) in order to better account for the impact of patient characteristics on post-procedure cognitive outcomes.
Key Question 1. In older adults who undergo selected cardiovascular procedures, what are the associated post-procedural cognitive outcomes?
- We found no evidence from eligible studies in older adults addressing whether there is a difference in intermediate or long-term cognitive outcomes after CABG vs. PCI, cardiac valve replacement vs. valve repair vs. medical management, or ablation versus medical management for atrial fibrillation.; - We found insufficient strength evidence from 1 observational study in older adults of no intermediate or long-term differences in multiple individual neuropsychological tests between patients who underwent CABG and those with coronary artery disease treated with medical management. | - Future studies (prospective cohorts, RCTs where appropriate considering noncognitive outcomes) should compare intermediate and long-term cognitive outcomes associated with more versus less invasive procedures (including medical management) for treatment of coronary and carotid vascular disease, cardiac valve disease, and atrial fibrillation in older adults.
Key Question 2. In older adults who undergo selected cardiovascular procedures, are associated risks for adverse post-procedural cognitive outcomes affected by procedural and peri-procedural stroke or TIA and other procedure characteristics?
- We could not determine whether risk for adverse intermediate or long-term cognitive outcomes following selected cardiovascular procedures was affected by procedural and peri-procedural stroke or TIA because, within eligible studies, strokes and TIAs were uncommon, risk for strokes and TIAs didn’t appear to differ between treatment groups, and risk for post-procedural cognitive outcomes also didn’t appear to differ between treatment groups.; - Though 5 eligible RCTs and 1 eligible observational study of on vs. off-pump CABG reported no difference in intermediate and long-term cognitive outcomes between these versions of CABG in older adults, SOE for this finding is only low.; - Though 3 eligible RCTs of hypothermic vs. normothermic CABG in older adults reported no difference in intermediate and long-term cognitive outcomes between these versions of CABG, SOE for this finding is low to moderate.; - Based on several comparisons, each reported in only 1 RCT, we found insufficient to low SOE that intermediate and long-term cognitive outcomes after CABG are not significantly different between older patients treated with a limited number of different anesthetic regimens, hyperbaric versus atmospheric oxygen, cell saver versus cardiotomy suction, high versus low blood pressure, or preoperative angiotensin-receptor blocker treatment versus placebo.; - Data from 1 small RCT suggested a potentially large reduction in cognitive impairment 3 months after CABG with minimal extracorporeal vs. conventional extracorporeal bypass. However, because the criterion for incident cognitive impairment was lenient (decline by >1 standard deviation in at least 1 of 7 neuropsychological tests) and there were few total events, the clinical relevance of this finding is uncertain. SOE for this finding is low. | - Future studies of cardiovascular procedures should include older adults at higher risk for stroke and should systematically collect information on procedural and peri-procedural stroke and TIA.; - Though additional RCTs of on vs. off-pump CABG and hypothermic vs. normothermic CABG may refine the relative estimates of effect for their associated intermediate and long-term cognitive outcomes, the difference between these pairs of treatments is likely to be small, if any, and future research efforts may better be directed to studying the intermediate and long-term cognitive impacts of other less investigated versions of CABG.; - In addition to reporting results for post-procedural cognitive outcomes overall, future studies should report results stratified by and/or adjusted for any procedure characteristics that are allowed to vary between participants as they may be important predictors of these post-procedural cognitive outcomes.; - A much larger RCT should randomize older adults to minimal extracorporeal vs. conventional extracorporeal bypass CABG and employ more rigorous cognitive outcomes and longer followup. RCTs with broader age ranges should perform stratified analyses by age and facilitate pooled analyses within an older age subgroup.
Key Question 3. In older adults who undergo selected cardiovascular procedures, are associated risks for adverse post-procedural cognitive outcomes affected by patient characteristics?
- We found no evidence from eligible studies in older adults undergoing selected cardiovascular procedures addressing whether selected patient characteristics (e.g., age; baseline cognitive function; past stroke or TIA, baseline CVD severity; hypertension; diabetes; depression) modify the association between these cardiovascular procedures and intermediate or long-term post-procedural cognitive outcomes.; - Eligible studies appeared to include few old-old participants (i.e., aged 80 years or older). Since the cardiovascular procedures of interest in this report are increasingly common in the old-old population, and this population is likely to be at greater risk for adverse cognitive outcomes, our findings may not be generalizable to this population.; - Based on reported results of pre-procedural cognitive testing, eligible studies appeared to include few participants with substantial baseline cognitive impairment, who are likely to be at greater risk for adverse cognitive outcomes after cardiovascular procedures, so our findings may not be generalizable to this population. | - Future studies (RCTs, controlled clinical trials (CCTs), prospective cohort studies) comparing intermediate and long-term cognitive outcomes between cardiovascular procedures should be conducted in patients with older ages and/or baseline cognitive impairment. Such patients have the highest risk for developing intermediate and long-term cognitive impairment after these procedures, and may also have larger differences in risk of these cognitive outcomes between different cardiovascular procedures.; - Future studies (RCTs, CCTs, prospective cohort studies) should enroll diverse patient populations and, in addition to reporting results for post-procedural cognitive outcomes in the population overall, they should also report results stratified by and/or adjusted for patient characteristics that may be important predictors of these post-procedural outcomes, or explore effect modification by these characteristics (e.g., age; baseline cognitive function; past stroke or TIA, baseline CVD severity; hypertension; diabetes; depression).

Abbreviations: CABG=coronary artery bypass grafting; CCT=controlled clinical trial; CVD=cardiovascular disease; PCI=percutaneous coronary intervention; RCT=randomized controlled trial; SD=standard deviation; TIA=transient ischemic attack