# Mean Change from Baseline Tables

Table 1 Mean change from baseline for [underlined: Trail Making A (time in seconds)], CABG studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Vedin 2006^3^ / Randomized trial | 6 | CABG, off-pump | 34 (11.5); n=33 | 32.0 (8.2); n=30 | −2.0 [−6.9 to 2.9] | 0.20 [−0.30 to 0.69] | 0.09 [−0.41 to 0.59]
Vedin 2006^3^ / Randomized trial | 6 | CABG, on-pump | 37 (16.7); n=37 | 34.0 (7.1); n=32 | −3.0 [−8.9 to 2.9] | 0.23 [−0.25 to 0.70]
Lee 2003^5^ / Randomized trial | 12 | CABG, off-pump | 47.4 (22.2); n=30 | 45.7 (15.2); n=27 | −1.7 [−11.5 to 8.1] | 0.09 [−0.43 to 0.61] | −0.05 [−0.59 to 0.49]
Lee 2003^5^ / Randomized trial | 12 | CABG, on-pump | 43.7 (32.6); n=30 | 43.4 (34.4); n=26 | −0.3 [−17.9 to 17.3] | 0.01 [−0.52 to 0.53]
Selnes 2009^20^ / Prospective observational | 12 | CABG, off-pump | 48.0 (23.0); n=69 | 43.4 (17.5); n=55 | −4.6 [−11.7 to 2.5] | 0.22 [−0.14, 0.58] | Off vs. On 0.08 [−0.24 to 0.40]
Selnes 2009^20^ / Prospective observational | 12 | CABG, on-pump | 47.1 (24.2); n=151 | 40.8 (16.8); n=123 | −6.3 [−11.2 to −1.4] | 0.30 [0.06 to 0.54] | Off vs. NSC −0.15 [−0.48 to 0.19]
Selnes 2009^20^ / Prospective observational | 12 | Non-surgical control | 43.1 (14.4); n=99 | 41.0 (15.6); n=91 | −2.1 [−6.4 to 2.2] | 0.14 [−0.15 to 0.42] | On vs. NSC −0.23 [−0.50 to 0.05]
Selnes 2009^20^ / Prospective observational
Selnes 2009^20^ / Prospective observational | 72 | CABG, off-pump | 48.0 (23.0); n=69 | 42.6 (15.9); n=43 | −5.4 [−12.6 to 1.8] | 0.26 [−0.12 to 0.64] | Off vs. On −0.24 [−0.60 to 0.13]
Selnes 2009^20^ / Prospective observational | 72 | CABG, on-pump | 47.1 (24.2); n=151 | 47.7 (29.5); n=95 | 0.6 [−6.5 to 7.7] | −0.02 [−0.28 to 0.23] | Off vs. NSC −0.37 [−0.76 to 0.02]
Selnes 2009^20^ / Prospective observational | 72 | Non-surgical control | 43.1 (14.4); n=99 | 46.4 (31.6); n=67 | 3.3 [−4.8 to 11.4] | −0.14 [−0.45 to 0.17] | On vs. NSC −0.10 [−0.41 to 0.21]
Nathan, 2001^7^ / Randomized trial | 60 | CABG, hypothermic | 38.7 (11.5); n=65 | NR | 6.5 (19.0); n=65 | NA | 0.27 [−0.08 to 0.61]
Nathan, 2001^7^ / Randomized trial | 60 | CABG, normothermic | 39.9 (11.6); n=66 | NR | 2.9 (1.8); n=66 | NA
Boodhwani 2007^6^/ Randomized trial | 3 | CABG, hypothermic | 41.9 (14.8); n=133 | NR | −4.0 (12.3); n=119 | NA | −0.21 [−0.47 to 0.04]
Boodhwani 2007^6^/ Randomized trial | 3 | CABG, normothermic | 40.2 (12.3); n=134 | NR | −1.4 (11.9); n=117 | NA
Alex 2005^13^ / Randomized trial | 4 | CABG, atmos. air | 41.7 (14.9); n=31 | 40.6 (15.7); n=31 | −1.1 [−8.7 to 6.5] | 0.07 [−0.43 to 0.57] | 0.03 [−0.46 to 0.52]
Alex 2005^13^ / Randomized trial | 4 | CABG, oxygen | 43.0 (16.3); n=33 | 41.4 (15.5); n=33 | −1.6 [−9.3 to 6.1] | 0.10 [−0.38 to 0.58]
Flesch 2009^11^ / Randomized trial | 3 | CABG, cardesartan | 43.2 (10.9); n=53 | 44.1 (14.5); n=43 | 0.9 [−4.3 to 6.1] | −0.07 [−0.47 to 0.33] | −0.33 [−0.75 to 0.10]
Flesch 2009^11^ / Randomized trial | 3 | CABG, placebo | 42.6 (10.7); n=53 | 47.2 (10.1); n=44 | 4.6 [0.5 to 8.8] | −0.44 [−0.84 to −0.03]
Gold 1995^15^ / Randomized trial | 6 | CABG, low MAP | 43.7 (22.3); n=124 | NR | −2.7 (15.4); n=113 | NA | 0.07 [−0.19 to 0.33]
Gold 1995^15^ / Randomized trial | 6 | CABG, high MAP | 45.2 (24.7); n=124 | NR | −4.0 (20.3); n=112 | NA
Kadoi 2003^14^ / Randomized trial | 6 | CABG, propofol | 42.5 (6.6); n=77 | 44.1 (5.7); n=77 | 1.6 [−0.4 to 3.6] | −0.26 [−0.58 to 0.06] | −0.10 [−0.41 to 0.22]
Kadoi 2003^14^ / Randomized trial | 6 | CABG, fentanyl | 43.2 (5.6); n=75 | 45.4 (6.9); n=75 | 2.2 [0.2 to 4.2] | −0.35 [−0.67 to −0.03]
Silbert 2006^12^ / Randomized trial | 12 | CABG, low-dose fentanyl | 55.0 (25.7); n=168 | 48.0 (18.1); n=159 | −7 [−11.8 to −2.2] | 0.31 [0.09 to 0.53] | −0.14 [−0.37 to 0.08]
Silbert 2006^12^ / Randomized trial | 12 | CABG, high-dose fentanyl | 54.6 (23.6); n=158 | 50.8 (22.6); n=140 | −3.8 [−9.1 to 1.5] | 0.16 [−0.06 to 0.39]

CI = confidence intervals; ES = effect size; PO = prospective observational study; RCT = randomized controlled trial; MAP = mean arterial pressure (during bypass); NSC = non-surgical control

Table 2 Mean change from baseline for [underlined: Trail Making A (time in seconds)], Carotid artery stenting (CAS) studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | 47.0 (17.0); n=20 | 46.3 (19.5); n=18 | −0.7 [−12.4 to 11.0] | 0.04 [−0.60 to 0.67] | −0.28 [−0.91 to 0.35]
Crawley 2000^17^ / Randomized trial | 6 | CEA | 68.8 (57.4); n=26 | 88.3 (119.4); n=22 | 19.5 [−35.1 to 74.1] | −0.21 [−0.78 to 0.36]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation;

Table 3 Mean change from baseline for [underlined: Trail Making A (time in seconds)], Carotid endarterectomy (CEA) studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^ / Randomized trial | 6 | CEA | 68.8 (57.4); n=26 | 88.3 (119.4); n=22 | 19.5 [−35.1 to 74.1] | −0.21 [−0.78 to 0.36] | 0.28 [−0.35 to 0.91]
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | 47.0 (17.0); n=20 | 46.3 (19.5); n=18 | −0.7 [−12.4 to 11.0] | 0.04 [−0.60 to 0.67]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation

Table 4 Mean change from baseline for [underlined: Verbal Fluency], CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Vedin, 2006^3^ / COWAT Randomized trial | 6 | CABG, off-pump | 30 (10.1); n=33 | 30 (5.8); n=30 | 0.0 [−4.0 to 4.0] | 0.00 [−0.49 to 0.49] | −0.56 [−1.06 to −0.05]
Vedin, 2006^3^ / COWAT Randomized trial | 6 | CABG, on-pump | 25 (7.6); n=37 | 29 (5.7); n=32 | 4 [0.9 to 7.2] | −0.58 [−1.07 to −0.10]
Lund, 2005^4^ / COWAT Randomized trial | 12 | CABG, off-pump | 34.0 (11.3); n=60 | 36.0 (13.3); n=54 | 2.0 [−2.6 to 6.6] | −0.16 [−0.53 to 0.21] | −0.02 [−0.40 to 0.36]
Lund, 2005^4^ / COWAT Randomized trial | 12 | CABG, off-pump | 36.4 (11.2); n=60 | 38.6 (12.0); n=52 | 2.2 [−2.1 to 6.5] | −0.19 [−0.56 to 0.18]
Djaiani, 2012^9^ / Randomized trial | 12 | CABG with cell-saver | 36.4 (12.6); n=85 | 38.1 (12.2); n=85 | 1.7 [−2.0 to 5.4] | −0.14 [−0.44 to 0.16] | −0.04 [−0.34 to 0.26]
Djaiani, 2012^9^ / Randomized trial | 12 | CABG with suction | 34.8 (10.6); n=83 | 37.0 (11.2); n=83 | 2.2 [−1.1 to 5.5] | −0.20 [−0.51 to 0.10]
Boodhwani, 2007^6^ / Randomized trial | 3 | CABG, hypothermic | 31.7 (12.1); n=133 | NR | 2.6 (7.2); n=119 | NA | 0.21 [−0.05 to 0.46]
Boodhwani, 2007^6^ / Randomized trial | 3 | CABG, normothermic | 32.2 (12.4); n=134 | NR | 1.0 (8.1); n=117 | NA
Flesch, 2009^11^ / Randomized trial | 3 | CABG, cardesartan | 61.7 (9.6); n=53 | 61.9 (10.8); n=43 | −0.20 [−4.34 to 3.94] | −0.02 [−0.42 to 0.38] | 0.04 [−0.38 to 0.46]
Flesch, 2009^11^ / Randomized trial | 3 | CABG, placebo | 57.8 (12.8); n=53 | 58.5 (12.9); n=44 | −0.70 [−5.84 to 4.44] | −0.05 [−0.45 to 0.35]
Gold, 1995^15^ / COWAT Randomized trial | 6 | CABG, low MAP | 37.5 (13.1); n=124 | NR | 0.0 (8.3) n=113 | NA | −0.08 [−0.34 to 0.18]
Gold, 1995^15^ / COWAT Randomized trial | 6 | CABG, high MAP | 37.6 (13.4); n=124 | NR | 0.6 (6.1) n=112 | NA
Silbert, 2006^12^ / COWAT Randomized trial | 12 | CABG, low-dose fentanyl | 33.1 (12.3); n=168 | 35.3 (12.0); n=159 | 2.2 [−0.4 to 4.8] | −0.18 [−0.40 to 0.04] | 0.02 [−0.21 to 0.24]
Silbert, 2006^12^ / COWAT Randomized trial | 12 | CABG, high-dose fentanyl | 31.4 (11.3); n=158 | 33.4 (12.9); n=141 | 2.0 [−0.8 to 4.8] | −0.17 [−0.39 to 0.06]

CI = confidence intervals; COWAT = Controlled Oral Word Association Test; ES = effect size; NSC = non-surgical control; SD = standard deviation

Table 5 Mean change from baseline for [underlined: Rey Auditory Verbal Learning Test (number of words)], CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Lund 2005^4^ / Randomized trial | 12 | CABG, off-pump | 33.6 (8.9); n=60 | 37.4 (10.7); n=54 | 3.8 [0.16 to 7.4] | −0.39 [−0.76 to −0.01] | −0.26 [−0.63 to 0.11]
Lund 2005^4^ / Randomized trial | 12 | CABG, off-pump | 35.7 (7.9); n=60 | 41.8 (7.9); n=52 | 6.1 [9.0 to 3.2] | −0.77 [−1.15 to −0.38]
Lee 2003^5^ / Randomized trial | 12 | CABG, off-pump | 36.1 (13.1); n=30 | 42.9 (12.0); n=27 | 6.8 [0.28 to 13.3] | −0.53 [−1.06 to −0.00] | 0.17 [−0.35 to 0.69]
Lee 2003^5^ / Randomized trial | 12 | CABG, on-pump | 39.2 (16.1); n=30 | 43.7 (14.8); n=26 | 4.5 [−3.6 to 12.6] | −0.29 [−0.81 to 0.24]
Selnes 2009^20^ / Prospective observational | 12 | CABG, off-pump | 38.5 (9.2); n=72 | 42.3 (10.3); n=55 | 3.8 [0.4 to 7.3] | −0.39 [−0.74 to −0.04] | Off vs. On −0.17 [−0.49 to 0.14]
Selnes 2009^20^ / Prospective observational | 12 | CABG, on-pump | 39.1 (8.8); n=152 | 44.6 (10.6); n=124 | 5.5 [3.2 to 7.8] | −0.57 [−0.81 to −0.33] | Off vs. NSC −0.05 [−0.39 to 0.28]
Selnes 2009^20^ / Prospective observational | 12 | Non-surgical control | 41.2 (8.8); n=99 | 45.5 (10.4); n=91 | 4.3 [1.6 to 7.1] | −0.45 [−0.73 to −0.16] | On vs. NSC 0.12 [−0.15 to 0.40]
Selnes 2009^20^ / Prospective observational
Selnes 2009^20^ / Prospective observational | 72 | CABG, off-pump | 38.5 (9.2); n=72 | 40.0 (11.2); n=43 | 1.5 [−2.5 to 5.5] | −0.15 [−0.53 to 0.23] | Off vs. On 0.12 [−0.24 to 0.48]
Selnes 2009^20^ / Prospective observational | 72 | CABG, on-pump | 39.1 (8.8); n=152 | 39.4 (10.4); n=96 | 0.3 [−2.2 to 2.8] | −0.03 [−0.29 to 0.22] | Off vs. NSC −0.02 [−0.40 to 0.36]
Selnes 2009^20^ / Prospective observational | 72 | Non-surgical control | 41.2 (8.8); n=99 | 42.9 (11.6); n=67 | 1.7 [−1.6 to 5.0] | −0.17 [−0.48 to 0.14] | On vs. NSC −0.15 [−0.46 to 0.17]
Djaiani 2012^9^ / Randomized trial | 12 | CABG with cell-saver | 7.0 (2.9); n=84 | 7.2 (3.4); n=84 | 0.2 [−0.8 to 1.2] | −0.06 [−0.37 to 0.24] | 0.16 [−0.15 to 0.46]
Djaiani 2012^9^ / Randomized trial | 12 | CABG with suction | 7.7 (2.9); n=84 | 7.4 (3.1); n=84 | −0.3 [−1.2 to 0.6] | 0.10 [−0.20 to 0.40]
Boodhwani 2007^6^/ Randomized trial | 3 | CABG, hypothermic | 37.8 (9.2); n=133 | NR | 0.3 (7.1); n=119 | NA | 0.18 [−0.08 to 0.43]
Boodhwani 2007^6^/ Randomized trial | 3 | CABG, normothermic | 38.4 (9.6); n=134 | NR | −1.0 (7.6) n=117 | NA
Alex 2005^13^ / Randomized trial | 4 | CABG, atmos. air | 41.2 (9.6); n=31 | 40.6 (10.4); n=31 | −0.6 [−5.6 to 4.4] | 0.06 [−0.44 to 0.56] | −0.21 [−0.70 to 0.28]
Alex 2005^13^ / Randomized trial | 4 | CABG, oxygen | 37.8 (11.5); n=33 | 39.4 (11): n=33 | 1.6 [−7.0 to 3.8] | −0.14 [−0.62 to 0.34]
Kadoi 2003^27^ / Randomized trial | 6 | CABG, propofol | Immediate recall 40.6 (6.6); n=77 | Immediate recall 43.1 (7.7); n=77 | 2.5 [0.2 to 4.8] | −0.35 [−0.67 to −0.03] | 0.01 [−0.31 to 0.33]
Kadoi 2003^27^ / Randomized trial | 6 | CABG, fentanyl | Immediate recall 42.7 (5.6); n=75 | Immediate recall 45.1 (11.7); n=75 | 2.4 [−0.5 to 5.3] | −0.26 [−0.58 to 0.06]
Kadoi 2003^27^ / Randomized trial
Kadoi 2003^27^ / Randomized trial | 6 | CABG, propofol | delayed recall 22.4 (3.9); n=77 | delayed recall 25.2 (5.4); n=77 | 2.8 [1.3 to 4.3] | −0.59 [−0.91 to −0.27] | 0.06 [−0.26 to 0.37]
Kadoi 2003^27^ / Randomized trial | 6 | CABG, fentanyl | delayed recall 23.1 (3.5); n=75 | delayed recall 25.6 (7.7); n=75 | 2.5 [0.6 to 4.4] | −0.42 [−0.74 to −0.09]

CI = confidence intervals; ES = effect size; PO = prospective observational study; RCT = randomized controlled trial; MAP = mean arterial pressure (during bypass); NSC = non-surgical control

Table 6 Mean change from baseline for [underlined: Rey Auditory Verbal Learning Test (number of words)], Carotid artery stenting (CAS) studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | 53.2 (12.3); n=20 | 53.9 (16.8); n=18 | 0.7 [−8.8 to 10.2] | −0.05 [−0.68 to 0.59] | −0.08 [−0.71 to 0.54]
Crawley 2000^17^ / Randomized trial | 6 | CEA | 53.9 (12.8); n=26 | 55.8 (14.9); n=22 | 1.9 [−6.0 to 9.8] | −0.14 [−0.70 to 0.43]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation

Table 7 Mean change from baseline for [underlined: Rey Auditory Verbal Learning Test (number of words)], Carotid endarterectomy (CEA) studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^ / Randomized trial | 6 | CEA | 53.9 (12.8); n=26 | 55.8 (14.9); n=22 | 1.9 [−6.0 to 9.8] | −0.14 [−0.70 to 0.43] | 0.08 [−0.54 to 0.71]
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | 53.2 (12.3); n=20 | 53.9 (16.8); n=18 | 0.7 [−8.8 to 10.2] | −0.05 [−0.68 to 0.59]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation deviation

Table 8 Mean change from baseline for [underlined: Trail Making B (time in seconds)], CABG studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Lamy, 2013^1^ / Randomized trial | 12 | CABG, off-pump | 158.0 (88.1); n=721 | NR | −6.8 (64.0); n=353 | NA | −0.05 [−0.20 to 0.10]
Lamy, 2013^1^ / Randomized trial | 12 | CABG, on-pump | 163.7 (89.5); n=711 | NR | −3.2 (70.2); n=340 | NA
Jensen 2008^2^/ Randomized trial | 12 | CABG, off-pump | 61.7 (24.9); n=61 | 66.7 (27.0); n=47 | −5.00 [−14.93 to 4.93] | −0.19 [−0.57 to 0.19] | −0.17 [−0.58 to 0.25]
Jensen 2008^2^/ Randomized trial | 12 | CABG, on-pump | 63.6 (23.4); n=59 | 64.4 (25.1); n=43 | −0.80 [−10.39, 8.79] | −0.03 [−0.43 to 0.36]
Vedin, 2006^3^ / Randomized trial | 6 | CABG, off-pump | 82 (28.7); n=33 | 84 (9.6); n=30 | 2.0 [−8.4 to 12.4] | −0.09 [−0.59 to 0.40] | 0.70 [0.19 to 1.22]
Vedin, 2006^3^ / Randomized trial | 6 | CABG, on-pump | 104 (54.7); n=37 | 83 (25.5); n=32 | −21 [−40.7 to -1.3] | 0.48 [−0.00 to 0.96]
Lee, 2003^5^ / Randomized trial | 12 | CABG, off-pump | 126.0 (86.7); n=30 | 117.3 (63.4); n=27 | −8.7 [−47.9 to 30.5] | 0.11 [−0.41 to 0.63] | 0.02 [−0.52 to 0.56]
Lee, 2003^5^ / Randomized trial | 12 | CABG, on-pump | 114.9 (87.6); n=30 | 104.4 (92.1); n=26 | −10.5 [−57.8 to 36.8] | 0.12 [−0.41 to 0.64]
Selnes, 2009^20^ / Prospective observational | 12 | CABG, off-pump | 96.9 (34.7); n=68 | 97.2 (48.4); n=55 | 0.3 [−14.9 to 15.5] | −0.01 [−0.36 to 0.35] | Off vs. On 0.20 [−0.12 to 0.52]
Selnes, 2009^20^ / Prospective observational | 12 | CABG, on-pump | 105.2 (59.0); n=147 | 95.4 (48.2); n=122 | −9.8 [−22.6 to 3.0] | 0.18 [−0.06 to 0.42] | Off vs. NSC 0.09 [−0.24 to 0.43]
Selnes, 2009^20^ / Prospective observational | 12 | Non-surgical control | 95.4 (40.0); n=99 | 92.0 (41.5); n=91 | −3.4 [−15.0 to 8.2] | 0.08 [−0.20 to 0.37] | On vs. NSC −0.13 [−0.40 to 0.14]
Selnes, 2009^20^ / Prospective observational
Selnes, 2009^20^ / Prospective observational | 72 | CABG, off-pump | 96.9 (34.7); n=68 | 101.4 (47.1); n=43 | 4.5 [−11.8 to 20.8] | −0.11 [−0.49, 0.27] | Off vs. On 0.09 [−0.27 to 0.45]
Selnes, 2009^20^ / Prospective observational | 72 | CABG, on-pump | 105.2 (59.0); n=147 | 105.0 (50.1); n=91 | −0.2 [−14.2 to 13.8] | 0.00 [−0.26 to 0.27] | Off vs. NSC −0.01 [−0.40 to 0.37]
Selnes, 2009^20^ / Prospective observational | 72 | Non-surgical control | 95.4 (40.0); n=99 | 100.4 (50.6); n=66 | 5.0 [−9.5 to 19.5] | −0.11 [−0.42 to 0.20] | On vs. NSC −0.10 [−0.42 to 0.21]
Nathan, 2001^7^ / Randomized trial | 60 | CABG, hypothermic | 104.3 (46.7); n=65 | NR | 24.2 (47.8); n=65 | NA | 0.22 [−0.12 to 0.56]
Nathan, 2001^7^ / Randomized trial | 60 | CABG, normothermic | 103.7 (9.2); n=66 | NR | 14.1 (43.6); n=66 | NA
Boodhwani, 2007^6^ / Randomized trial | 3 | CABG, hypothermic | 105.6 (45.0); n=133 | NR | −11.7 (29.0); n=119 | NA | −0.12 [−0.38 to 0.14]
Boodhwani, 2007^6^ / Randomized trial | 3 | CABG, normothermic | 103.3 (43.3); n=134 | NR | −7.8 (35.5); n=117 | NA
Alex, 2005^13^ / Randomized trial | 4 | CABG, atmos. air | 101 (43.5); n=31 | 107 (54.7); n=31 | 6.0 [−18.6 to 30.6] | −0.12 [−0.62 to 0.38] | 0.50 [0.00 to 1.00]
Alex, 2005^13^ / Randomized trial | 4 | CABG, oxygen | 127.1 (52.6); n=33 | 108.7 (45.5); n=33 | −18.4 [−42.1 to 5.3] | 0.37 [−0.12 to 0.86]
Flesch, 2009^11^ / Randomized trial | 3 | CABG, cardesartan | 40.5 (10.1); n=53 | 44.8 (11.3); n=43 | 4.3 [−0.04 to 8.6] | −0.40 [−0.81 to 0.01] | −0.05 [−0.47 to 0.37]
Flesch, 2009^11^ / Randomized trial | 3 | CABG, placebo | 40.7 (10.9); n=53 | 45.5 (12.8); n=44 | 4.8 [0.01 to 9.6] | −0.40 [−0.81 to 0.00]
Gold, 1995^15^ / Randomized trial | 6 | CABG, low MAP | 104.6 (60.8); n=124 | NR | −3.6 (46.9); n=113 | NA | 0.24 [−0.03 to 0.50]
Gold, 1995^15^ / Randomized trial | 6 | CABG, high MAP | 102.6 (49.3); n=124 | NR | −13.9 (39.3); n=112 | NA
Kadoi, 2003^27^ / Randomized trial | 6 | CABG, propofol | 154.2 (51.1); n=77 | 164.0 (63.4); n=77 | 9.8 [−8.4 to 28.0] | −0.17 [−0.49 to 0.15] | −0.18 [−0.49 to 0.14]
Kadoi, 2003^27^ / Randomized trial | 6 | CABG, fentanyl | 156.3 (50.3); n=75 | 176.0 (57.0); n=75 | 19.7 [2.5 to 36.9] | −0.36 [−0.69 to -0.04]
Silbert, 2006^12^ / Randomized trial | 12 | CABG, low-dose fentanyl | 125.7 (62.5); n=168 | 110.5 (58.1); n=158 | −15.2 [−28.3 to -2.1] | 0.25 [0.03 to 0.47] | −0.08 [−0.31 to 0.15]
Silbert, 2006^12^ / Randomized trial | 12 | CABG, high-dose fentanyl | 127.5 (62.4); n=158 | 117.1 (58.9); n=141 | −10.4 [−24.2 to 3.4] | 0.17 [−0.06 to 0.40]

CI = confidence intervals; ES = effect size; MAP = mean arterial pressure (during bypass); NSC = non-surgical control; SD = standard deviation

Table 9 Mean change from baseline for [underlined: Trail Making B (time in seconds)], Carotid artery stenting (CAS) studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | 129.5 (76.8); n=20 | 152.9 (113.7); n=18 | 23.4 [−39.0 to 85.8] | −0.24 [−0.88 to 0.40] | 0.26 [−0.37 to 0.88]
Crawley 2000^17^ / Randomized trial | 6 | CEA | 144.0 (49.2); n=26 | 147.0 (70.6); n=22 | 3.0 [−32.0 to 38.0] | −0.05 [−0.62 to 0.52]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation

Table 10 Mean change from baseline for [underlined: Trail Making B (time in seconds)], Carotid endarterectomy (CEA) studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^/ Randomized trial | 6 | CEA | 144.0 (49.2); n=26 | 147.0 (70.6); n=22 | 3.0 [−32.0 to 38.0] | −0.05 [−0.62 to 0.52] | −0.26 [−0.88 to 0.37]
Crawley 2000^17^/ Randomized trial | 6 | Carotid PTA | 129.5 (76.8); n=20 | 152.9 (113.7); n=18 | 23.4 [−39.0 to 85.8] | −0.24 [−0.88, 0.40]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation;

Table 11 Mean change from baseline for [underlined: Grooved Pegboard Test (seconds)], CABG studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Lund, 2005^4^ / Randomized trial | 12 | CABG, off-pump | 84.5 (19.3); n=60 | 78.8 (16.8); n=54 | −5.7 [−12.3 to 0.9] | 0.31 [−0.06 to 0.68] | −0.19 [−0.57 to 0.19]
Lund, 2005^4^ / Randomized trial | 12 | CABG, off-pump | 81.3 (16.9); n=60 | 78.8 (16.1); n=52 | −2.5 [−8.6 to 3.6] | 0.15 [−0.22, 0.52]
Lee 2003^5^ / Randomized trial | 12 | CABG, off-pump | Dominant 97.8 (30.7); n=30 | Dominant 91.5 (26.0); n=27 | −6.3 [−21.0 to 8.4] | 0.22 [−0.30 to 0.74] | −0.03 [−0.57 to 0.51]
Lee 2003^5^ / Randomized trial | 12 | CABG, on-pump | Dominant 96.8 (46.9); n=30 | Dominant 91.5 (26.0); n=26 | −5.3 [−24.8 to 14.2] | 0.14 [−0.39 to 0.66]
Lee 2003^5^ / Randomized trial
Lee 2003^5^ / Randomized trial | 12 | CABG, off-pump | Non-dominant 100.9 (124.5); n=30 | Non-dominant 97.6 (32.2); n=27 | −3.3 [−49.5 to 42.3] | 0.03 [−0.49 to 0.55] | −0.19 [−0.57 to 0.19]
Lee 2003^5^ / Randomized trial | 12 | CABG, on-pump | Non-dominant 97.2 (37.2); n=30 | Non-dominant 89.6 (29.6); n=26 | −7.6 [−25.1 to 9.9] | 0.22 [−0.31 to 0.75]
Selnes 2009^20^ / Prospective observational | 12 | CABG, off-pump | Dominant 99.6 (30.9); n=67 | Dominant 94.2 (32.1); n=54 | −5.4 [−16.7 to 5.9] | 0.17 [−0.19 to 0.53] | Off vs. On 0.16 [−0.16 to 0.48]
Selnes 2009^20^ / Prospective observational | 12 | CABG, on-pump | Dominant 107.5 (53.7); n=152 | Dominant 95.6 (29.9); n=122 | −11.9 [−1.9 to -22.0] | 0.27 [0.03 to 0.50] | Off vs. NSC 0.06 [−0.28 to 0.40]
Selnes 2009^20^ / Prospective observational | 12 | Non-surgical control | Dominant 97.9 (29.7); n=99 | Dominant 90.8 (24.6); n=91 | −7.1 [−14.8 to 0.6] | 0.26 [−0.03 to 0.54] | On vs. NSC −0.13 [−0.40 to 0.14]
Selnes 2009^20^ / Prospective observational
Selnes 2009^20^ / Prospective observational | 12 | CABG, off-pump | Non-dominant 107.0 (34.4); n=68 | Non-dominant 98.1 (30.3); n=54 54 | −8.9 [−20.4 to 2.6] | 0.27 [−0.09 to 0.63] | Off vs. On 0.17 [−0.16 to 0.49]
Selnes 2009^20^ / Prospective observational | 12 | CABG, on-pump | Non-dominant 119.1 (65.3); n=149 | Non-dominant 103.4 (30.6); n=123 | −15.7 [−27.5 to -3.9] | 0.30 [0.06 to 0.54] | Off vs. NSC −0.11 [−0.45 to 0.23]
Selnes 2009^20^ / Prospective observational | 12 | Non-surgical control | Non-dominant 107.4 (38.4); n=98 | Non-dominant 102.5 (35.6); n=89 | −4.9 [−15.5 to 5.7] | 0.13 [−0.16 to 0.42] | On vs. NSC −0.26 [−0.54 to 0.01]
Selnes 2009^20^ / Prospective observational
Selnes 2009^20^ / Prospective observational | 72 | CABG, off-pump | Dominant 99.6 (30.9); n=67 | Dominant 96.0 (34.4); n=43 | −3.6 [−16.3 to 9.1] | 0.11 [−0.27 to 0.49] | Off vs. On −0.04 [−0.40 to 0.32]
Selnes 2009^20^ / Prospective observational | 72 | CABG, on-pump | Dominant 107.5 (53.7);n=152 | Dominant 105.5 (36.0); n=93 | −2.0 [−13.2 to 9.2] | 0.04 [−0.22 to 0.30] | Off vs. NSC −0.25 [−0.64 to 0.13]
Selnes 2009^20^ / Prospective observational | 72 | Non-surgical control | Dominant 97.9 (29.7); n=99 | Dominant 103.3 (42.0); n=67 | 5.4 [−6.2 to 17.0] | −0.15 [−0.46 to 0.16] | On vs. NSC −0.18 [−0.49 to 0.13]
Selnes 2009^20^ / Prospective observational
Selnes 2009^20^ / Prospective observational | 72 | CABG, off-pump | Non-dominant 107.0 (34.4); n=68 | Non-dominant 99.0 (30.4); n=43 | −8.0 [−20.2 to 4.2] | 0.24 [−0.14 to 0.62] | Off vs. On −0.11 [−0.47 to 0.25]
Selnes 2009^20^ / Prospective observational | 72 | CABG, on-pump | Non-dominant 119.1 (65.3); n=149 | Non-dominant 116.3 (41.3); n=94 | −2.8 [−16.2 to 10.6] | 0.05 [−0.21 to 0.31] | Off vs. NSC −0.32 [−0.71 to 0.06]
Selnes 2009^20^ / Prospective observational | 72 | Non-surgical control | Non-dominant 107.4 (38.4); n=98 | Non-dominant 111.6 (42.9); n=66 | 4.2 [−8.6 to 17.0] | −0.10 [−0.42 to 0.21] | On vs. NSC −0.15 [−0.46 to 0.17]
Djaiani 2012^9^/ Randomized trial | 12 | CABG with cell-saver | 90.0 (18.7); n=84 | 89.1 (18.8); n=84 | −0.9 [−6.6 to 4.8] | 0.05 [−0.25 to 0.35] | 0.20 [−0.10 to 0.51]
Djaiani 2012^9^/ Randomized trial | 12 | CABG with suction | 91.3 (21.9); n=83 | 86.1 (23.4); n=83 | −5.2 [−12.1 to 1.7] | 0.23 [−0.08 to 0.53]
Boodhwani 2007^6^ / Randomized trial | 3 | CABG, hypothermic | Dominant 90.1 (20.5); n=133 | Dominant NR | −4.0 (13.4); n=119 | NA | −0.14 [−0.40 to 0.11]
Boodhwani 2007^6^ / Randomized trial | 3 | CABG, normothermic | Dominant 91.1 (24.4); n=134 | Dominant NR | −2.0 (14.8); n=117 | NA
Boodhwani 2007^6^ / Randomized trial
Boodhwani 2007^6^ / Randomized trial | 3 | CABG, hypothermic | Non-dominant 99.2 (26.6); n=133 | Non-dominant NR | −4.3 (18.2); n=119 | NA | −0.05 [−0.30 to 0.21]
Boodhwani 2007^6^ / Randomized trial | 3 | CABG, normothermic | Non-dominant 100.1 (28.3); n=134 | Non-dominant NR | −3.5 (13.7); n=117 | NA
Nathan 2001^7^/ Randomized trial | 60 | CABG, hypothermic | 88.2 (17.0); n=65 | NR | 14.7 (30.7); n=65 | NA | 0.04 [−0.31 to 0.38]
Nathan 2001^7^/ Randomized trial | 60 | CABG, normothermic | 87.5 (20.7); n=66 | NR | 13.7 (21.6); n=66 | NA
Alex 2005 / Randomized trial | 4 | CABG, atmos. air | Dominant 19.1 (2.2); n=31 | Dominant 19.1 (2.6); n=31 | 0.0 [−1.2 to 1.2] | 0.00 [−0.50 to 0.50] | 0.24 [−0.26 to 0.73]
Alex 2005 / Randomized trial | 4 | CABG, oxygen | Dominant 19.7 (2.8); n=33 | Dominant 19.1 (2.5); n=33 | −0.6 [−1.9 to 0.7] | 0.22 [−0.26 to 0.71]
Alex 2005 / Randomized trial
Alex 2005 / Randomized trial | 4 | CABG, atmos. air | Non-dominant 21.0 (2.3); n=31 | Non-dominant 20.4 (2.6); n=31 | −0.6 [−1.8 to 0.6] | 0.24 [−0.26 to 0.74] | −0.17 [−0.67 to 0.32]
Alex 2005 / Randomized trial | 4 | CABG, oxygen | Non-dominant 21.0 (3.0); n=33 | Non-dominant 20.9 (3.7); n=33 | −0.1 [−1.7 to 1.5] | 0.03 [−0.45 to 0.51]
Kadoi 2003^27^ / Randomized trial | 6 | CABG, propofol | 21.9 (3.0); n=77 | 23.2 (4.0); n=77 | 1.3 [0.2 to 2.4] | −0.37 [−0.68 to -0.05] | 0.03 [−0.29 to 0.34]
Kadoi 2003^27^ / Randomized trial | 6 | CABG, fentanyl | 22.0 (3.5); n=75 | 23.2 (4.3); n=75 | 1.2 [−0.1 to 2.5] | −0.30 [−0.63 to 0.02]
Silbert 2006^12^ / Randomized trial | 12 | CABG, low-dose fentanyl | Dominant 99.7 (30.6); n=165 | Dominant 90.6 (30.7); n=155 | −9.1 [−15.8 to -2.4] | 0.30 [0.08 to 0.52] | 0.05 [−0.18 to 0.27]
Silbert 2006^12^ / Randomized trial | 12 | CABG, high-dose fentanyl | Dominant 102.1 (34.5); n=155 | Dominant 91.6 (28.0); n=138 | −10.5 [−17.7 to -3.3] | 0.33 [0.10 to 0.56]
Silbert 2006^12^ / Randomized trial
Silbert 2006^12^ / Randomized trial | 12 | CABG, low-dose fentanyl | Non-dominant 110.2 (39.2); n=166 | Non-dominant 100.1 (34.3); n=155 | −10.1 [−18.1 to -2.1] | 0.27 [0.05 to 0.49] | −0.01 [−0.24 to 0.22]
Silbert 2006^12^ / Randomized trial | 12 | CABG, high-dose fentanyl | Non-dominant 108.5 (37.8); n=152 | Non-dominant 98.6 (22.3); n=136 | −9.9 [−17.0 to -2.8] | 0.31 [0.08 to 0.55]

CI = confidence intervals; ES = effect size; NSC = non-surgical control; SD = standard deviation

Table 12 Mean change from baseline for [underlined: Grooved Pegboard Test (seconds)], Carotid artery stenting (CAS) studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | Dominant 89.3 (21.8); n=20 | Dominant 103.8 (34.3); n=18 | 14.5 [−4.0 to 33.0] | −0.50 [−1.15 to 0.15] | 0.37 [−0.26 to 1.00]
Crawley 2000^17^ / Randomized trial | 6 | CEA | Dominant 106.6 (33.6); n=26 | Dominant 108.8 (39.6); n=22 | 2.2 [−18.8 to 23.2] | −0.06 [−0.63 to 0.51]
Crawley 2000^17^ / Randomized trial
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | Non-dominant 109.4 (32.2); n=20 | Non-dominant 120.4 (47.8); n=18 | 11.0 [−15.2 to 37.2] | −0.27 [−0.91 to 0.37] | −0.05 [−0.67 to 0.58]
Crawley 2000^17^ / Randomized trial | 6 | CEA | Non-dominant 113.3 (26.3); n=26 | Non-dominant 126.5 (65.7); n=22 | 13.2 [−16.1 to 42.5] | −0.27 [−0.84 to 0.30]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation

Table 13 Mean change from baseline for [underlined: Grooved Pegboard Test (seconds)], Carotid endarterectomy (CEA) studies. Lower scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n | ES [95%CI] within groups | ES [95%CI] between groups
Crawley 2000^17^ / Randomized trial | 6 | CEA | Dominant 106.6 (33.6); n=26 | Dominant 108.8 (39.6); n=22 | 2.2 [−18.8 to 23.2] | −0.06 [−0.63 to 0.51] | −0.37 [−1.00 to 0.26]
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | Dominant 89.3 (21.8); n=20 | Dominant 103.8 (34.3); n=18 | 14.5 [−4.0 to 33.0] | −0.50 [−1.15 to 0.15]
Crawley 2000^17^ / Randomized trial
Crawley 2000^17^ / Randomized trial | 6 | CEA | Non-dominant 113.3 (26.3); n=26 | Non-dominant 126.5 (65.7); n=22 | 13.2 [−16.1 to 42.5] | −0.27 [−0.84 to 0.30] | 0.05 [−0.58 to 0.67]
Crawley 2000^17^ / Randomized trial | 6 | Carotid PTA | Non-dominant 109.4 (32.2); n=20 | Non-dominant 120.4 (47.8); n=18 | 11.0 [−15.2 to 37.2] | −0.27 [−0.91 to 0.37]

CI = confidence intervals; ES = effect size; PTA = Percutaneous transluminal angioplasty; SD = standard deviation

Table 14 Mean change from baseline for [underlined: Digit Span Test], CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Vedin, 2006^3^/ Randomized trial | 6 | CABG, off-pump | forward 7.4 (1.7); n=33 | forward 7.2 (1.1); n=30 | forward 0.20 [−0.50 to 0.90] | forward 0.14 [−0.36 to 0.63] | forward 0.17 [−0.33 to 0.67]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, on-pump | forward 7.1 (2.3); n=37 | forward 7.2 (1.8); n=32 | forward −0.10 [−1.07 to 0.87] | forward −0.05 [−0.52 to 0.43]
Vedin, 2006^3^/ Randomized trial
Vedin, 2006^3^/ Randomized trial | 6 | CABG, off-pump | backward 6.2 (1.6); n=33 | backward 6.7 (1.5); n=30 | backward −0.50 [−1.27 to 0.27] | backward −0.32 [−0.82 to 0.18] | backward 0.07 [−0.43 to 0.57]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, on-pump | backward 5.6 (1.7); n=37 | backward 6.2 (1.0); n=32 | backward −0.60 [−1.25 to 0.05] | backward −0.42 [−0.90 to 0.06]
Lund, 2005^4^/ Randomized trial | 12 | CABG, off-pump | 9.8 (1.4); n=54 | 9.9 (1.6); n=54 | −0.10 [−0.67 to 0.47] | −0.07 [−0.44 to 0.31] | 0.13 [−0.25 to 0.51]
Lund, 2005^4^/ Randomized trial | 12 | CABG, on-pump | 10.4 (2.0); n=52 | 10.8 (3.5); n=52 | −0.40 [−1.50 to 0.70] | −0.14 [−0.52 to 0.25]
Anastasiadis 2011^10^/ Randomized trial | 3 | CABG with MECC | forward 6.5 (1.5); n=29 | forward 6.9 (1.8); n=29 | forward −0.40 [−1.25 to 0.45] | forward −0.24 [−0.75 to 0.28] | forward −0.46 [−0.98 to 0.05]
Anastasiadis 2011^10^/ Randomized trial | 3 | CABG with CECC | forward 6.7 (2.1); n=31 | forward 6.3 (1.5); n=31 | forward 0.40 [−0.51 to 1.31] | forward 0.22 [−0.28 to 0.72]
Anastasiadis 2011^10^/ Randomized trial
Anastasiadis 2011^10^/ Randomized trial | 3 | CABG with MECC | backward 4.3 (1.6); n=29 | backward 4.7 (1.4); n=29 | backward −0.40 [−1.17 to 0.37] | backward −0.26 [−0.78 to 0.25] | backward −0.76 [−1.28 to −0.23]
Anastasiadis 2011^10^/ Randomized trial | 3 | CABG with CECC | backward 4.1 (1.5); n=31 | backward 3.5 (1.0); n=31 | backward 0.60 [−0.03 to 1.23] | backward 0.46 [−0.04 to 0.97]
Djaiani 2012^9^/ Randomized trial | 12 | CABG with cell-saver | forward 10.1 (2.4); n=83 | forward 10.1 (1.4); n=83 | forward 0.00 [−0.60 to 0.60] | forward 0.00 [−0.30 to 0.30] | forward 0.15 [−0.15 to 0.46]
Djaiani 2012^9^/ Randomized trial | 12 | CABG with suction | forward 10.2 (2.0); n=82 | forward 10.5 (1.8); n=82 | forward −0.30 [−0.88 to 0.28] | forward −0.16 [−0.46 to 0.15]
Djaiani 2012^9^/ Randomized trial
Djaiani 2012^9^/ Randomized trial | 12 | CABG with cell-saver | backward 6.3 (2.3); n=84 | backward 6.7 (2.5); n=84 | backward −0.40 [−1.13 to 0.33] | backward −0.17 [−0.47 to 0.14] | backward −0.25 [−0.56 to 0.05]
Djaiani 2012^9^/ Randomized trial | 12 | CABG with suction | backward 6.4 (2.5); n=85 | backward 6.2 (2.1); n=85 | backward 0.20 [−0.49 to 0.89] | backward 0.09 [−0.21 to 0.39]
Boodhwani, 2007^6^/ Randomized trial | 3 | CABG, hypothermic | forward 9.7 (2.2); n=133 | NR | forward 0.3 (1.7); n=119 | NA | forward 0.00 [−0.26 to 0.26]
Boodhwani, 2007^6^/ Randomized trial | 3 | CABG, normothermic | forward 9.6 (2.0); n=134 | NR | forward 0.3 (1.7); n=117 | NA
Boodhwani, 2007^6^/ Randomized trial
Boodhwani, 2007^6^/ Randomized trial | 3 | CABG, hypothermic | backward 6.1 (2.1); n=133 | NR | backward 0.5 (1.9); n=119 | backward | backward 1.93 [1.62 to 2.24]
Boodhwani, 2007^6^/ Randomized trial | 3 | CABG, normothermic | backward 6.3 (2.1); n=134 | NR | backward −0.3 (1.7); n=117 | backward
Nathan 2001^7^/ Randomized trial | 60 | CABG, hypothermic | forward 7.3 (2.5); n=65 | NR | forward −0.3 (2.0); n=65 | NA | forward 0.17 [−0.17 to 0.51]
Nathan 2001^7^/ Randomized trial | 60 | CABG, normothermic | forward 8.2 (2.3); n=66 | NR | forward −0.6 (1.5); n=66 | NA
Nathan 2001^7^/ Randomized trial
Nathan 2001^7^/ Randomized trial | 60 | CABG, hypothermic | backward 6.2 (2.4); n=65 | NR | backward −0.1 (1.9); n=65 | NA | backward 0.00 [−0.34 to 0.34]
Nathan 2001^7^/ Randomized trial | 60 | CABG, normothermic | backward 6.8 (2.7); n=66 | NR | backward −0.1 (2.2); n=66 | NA
Alex, 2005^13^/ Randomized trial | 4 | CABG, atmos. air | forward 9.9 (2.7); n=31 | forward 9.5 (2.6); n=31 | forward 0.40 [−0.92 to 1.72] | forward 0.15 [−0.35 to 0.65] | forward 0.28 [−0.22 to 0.77]
Alex, 2005^13^/ Randomized trial | 4 | CABG, oxygen | forward 8.9 (2.3); n=33 | forward 9.2 (2.5); n=33 | forward −0.30 [−1.46 to 0.86] | forward −0.12 [−0.61 to 0.36]
Alex, 2005^13^/ Randomized trial
Alex, 2005^13^/ Randomized trial | 4 | CABG, atmos. air | backward 6.8 (2.5); n=31 | backward 6.3 (2.2); n=31 | backward 0.50 [−0.67 to 1.67] | backward 0.21 [−0.29 to 0.71] | backward 0.31 [−0.18 to 0.81]
Alex, 2005^13^/ Randomized trial | 4 | CABG, oxygen | backward 5.9 (2.1); n=33 | backward 6.1 (2.1); n=33 | backward −0.20 [−1.21 to 0.81] | backward −0.09 [−0.58 to 0.39]
Flesch, 2009^11^/ Randomized trial | 3 | CABG, cardesartan | forward 48.8 (10.1); n=53 | forward 47.9 (9.2); n=43 | forward 0.90 [−2.97 to 4.77] | forward 0.09 [−0.31 to 0.49] | forward 0.17 [−0.25 to 0.59]
Flesch, 2009^11^/ Randomized trial | 3 | CABG, placebo | forward 50.0 (11.0); n=53 | forward 50.8 (10.7); n=44 | forward −0.80 [−5.13 to 3.53] | forward −0.07 [−0.47 to 0.33]
Flesch, 2009^11^/ Randomized trial
Flesch, 2009^11^/ Randomized trial | 3 | CABG, cardesartan | backward 47.0 (10.0); n=53 | backward 46.7 (8.5); n=43 | backward 0.30 [−3.40 to 4.00] | backward 0.03 [−0.37 to 0.43] | backward −0.04 [−0.46 to 0.38]
Flesch, 2009^11^/ Randomized trial | 3 | CABG, placebo | backward 47.8 (10.4); n=53 | backward 47.1 (10.0); n=44 | backward 0.70 [−3.37 to 4.77] | backward 0.07 [−0.33 to 0.47]
Gold, 1995^15^/ Randomized trial | 6 | CABG, low MAP | 14.8 (3.9); n=124 | NR | 0.0 (3.1); n=113 | NA | −0.13 [−0.39 to 0.13]
Gold, 1995^15^/ Randomized trial | 6 | CABG, high MAP | 14.2 (4.0); n=124 | NR | 0.4 (2.9); n=112 | NA
Kadoi, 2003^27^/ Randomized trial | 6 | CABG, propofol | forward 7.6 (2.0); n=77 | forward 8.0 (2.2); n=77 | forward −0.40 [−1.06 to 0.26] | forward −0.19 [−0.51 to 0.13] | forward −0.09 [−0.41 to 0.23]
Kadoi, 2003^27^/ Randomized trial | 6 | CABG, fentanyl | forward 7.5 (2.2); n=75 | forward 7.7 (2.4); n=75 | forward −0.20 [−0.94 to 0.54] | forward −0.09 [−0.41 to 0.23]

CI = confidence intervals; ES = effect size; PO = prospective observational study; RCT = randomized controlled trial; MAP = mean arterial pressure (during bypass); NSC = non-surgical control

Table 15 Mean change from baseline for [underlined: Digit Symbol Test], CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Lamy, 2013^1^/ Randomized trial | 12 | CABG, off-pump | 33.0 (17.8); n=989 | NR | 1.8 (13.2); n=522 | NA | 0.04 [−0.08 to 0.16]
Lamy, 2013^1^/ Randomized trial | 12 | CABG, on-pump | 31.9 (18.0); n=986 | NR | 1.3 (12.3); n=528 | NA
Jensen 2008^2^/ Randomized trial | 12 | CABG, off-pump | 21.4 (6.4); n=61 | 22.3 (6.4); n=47 | −0.90 [−3.33 to1.53] | −0.14 [−0.52 to 0.24] | 0.02 [−0.40 to 0.43]
Jensen 2008^2^/ Randomized trial | 12 | CABG, on-pump | 20.5 (5.6); n=59 | 21.5 (6.1); n=43 | −1.00 [−3.32 to 1.32] | −0.17 [−0.56 to 0.22]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, off-pump | Symbol A 5.6 (2.3); n=33 | Symbol A 5.7 (1.4); n=30 | Symbol A −0.10 [−1.03 to 0.83] | Symbol A −0.05 [−0.55 to 0.44] | Symbol A 0.47 [−0.04 to 0.97]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, on-pump | Symbol A 5.0 (2.6); n=37 | Symbol A 6.0 (1.6); n=32 | Symbol A −1.00 [−2.00 to 0.00] | Symbol A −0.45 [−0.93 to 0.03]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, off-pump | Free recall 7.4 (1.6); n=33 | Free recall 7.7 (0.9); n=30 | Free recall −0.30 [−0.93 to 0.33] | Free recall −0.23 [−0.72 to 0.27] | Free recall 0.16 [−0.34 to 0.66]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, on-pump | Free recall 7.1 (1.5); n=37 | Free recall 7.6 (0.9); n=32 | Free recall −0.50 [−1.08 to 0.08] | Free recall −0.39 [−0.87 to 0.09]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, off-pump | 90 seconds 40 (9.9); n=33 | 90 seconds 42 (4.1); n=30 | 90 seconds −2.00 [−5.68 to 1.68] | 90 seconds −0.26 [−0.75 to 0.24] | 90 seconds 0.12 [−0.38 to 0.62]
Vedin, 2006^3^/ Randomized trial | 6 | CABG, on-pump | 90 seconds 36 (10.6); n=37 | 90 seconds 39 (7.1); n=32 | 90 seconds −3.00 [−7.21 to 1.21] | 90 seconds −0.32 [−0.80 to 0.15]
Lund 2005^4^/ Randomized trial | 12 | CABG, off-pump | 36.6 (8.9); n=60 | 38.5 (10.2); n=54 | −1.90 [−5.43 to 1.63] | −0.20 [−0.57 to 0.17] | 0.08 [−0.30 to 0.46]
Lund 2005^4^/ Randomized trial | 12 | CABG, on-pump | 36.4 (9.6); n=60 | 39.1 (10.1); n=52 | −2.70 [−6.33 to 0.93] | −0.27 [−0.64 to 0.10]
Lee 2003^5^/ Randomized trial | 12 | CABG, off-pump | 45.3 (17.0); n=30 | 43.7 (14.5); n=27 | 1.60 [−6.58 to 9.78] | 0.10 [−0.42 to 0.62] | 0.16 [−0.38 to 0.70]
Lee 2003^5^/ Randomized trial | 12 | CABG, on-pump | 52.5 (17.0); n=30 | 53.8 (22.1); n=26 | −1.30 [−11.62 to 9.02] | −0.07 [−0.59 to 0.45]
Boodhwani 2007^6^/ Randomized trial | 3 | CABG, hypothermic | 42.9 (9.4); n=133 | NR | 2.1 (5.3); n=119 | NA | 0.05 [−0.21 to 0.30]
Boodhwani 2007^6^/ Randomized trial | 3 | CABG, normothermic | 43.1 (9.7); n=134 | NR | 1.8 (6.7); n=117 | NA
Anastasiadis 2011^10^/ Randomized trial | 3 | CABG with MECC | 36.7 (15.9); n=29 | 43.2 (17.1); n=29 | −6.50 [−15.00 to 2.00] | −0.39 [−0.91 to 0.13] | −0.71 [−1.23 to −0.19]
Anastasiadis 2011^10^/ Randomized trial | 3 | CABG with CECC | 29.7 (17.2); n=31 | 24.2 (17.7); n=31 | 5.50 [−3.19 to 14.19] | 0.31 [−0.19 to 0.81]
Gold, 1995^15^/ Randomized trial | 6 | CABG, low MAP | 40.9 (13.7); n=124 | NR | 2.5 (5.9); n=113 | NA | −0.19 [−0.45 to 0.07]
Gold, 1995^15^/ Randomized trial | 6 | CABG, high MAP | 41.4 (10.7); n=124 | NR | 3.7 (6.7); n=112 | NA
Silbert, 2006^12^/ Randomized trial | 12 | CABG, low-dose fentanyl | 34.8 (9.7); n=168 | 38.9 (10.9); n=159 | −4.10 [−6.34 to -1.86] | −0.40 [−0.62 to −0.18] | −0.07 [−0.29 to 0.16]
Silbert, 2006^12^/ Randomized trial | 12 | CABG, high-dose fentanyl | 33.7 (10.3); n=158 | 37.1 (10.9); n=141 | −3.40 [−5.81 to −0.99] | −0.32 [−0.55 to −0.09]

CI = confidence intervals; ES = effect size; PO = prospective observational study; RCT = randomized controlled trial; MAP = mean arterial pressure (during bypass); NSC = non-surgical control

Table 16 Mean change from baseline for [underlined: Block Design (raw score)], CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Lund 2005^4^/ Randomized trial | 12 | CABG, off-pump | 26.4 (8.5); n=60 | 27.4 (9.7); n=54 | −1.00 [−4.36 to 2.36] | −0.11 [−0.48 to 0.26] | 0.01 [−0.37 to 0.39]
Lund 2005^4^/ Randomized trial | 12 | CABG, on-pump | 26.7 (9.2); n=60 | 27.8 (9.6); n=52 | −1.10 [−4.60 to 2.40] | −0.12 [−0.49 to 0.26]
Selnes, 2009^20^/ Prospective observational | 12 | CABG, off-pump | 22.9 (9.2); n=69 | 26.0 (9.6); n=54 | −3.10 [−6.46 to 0.26] | −0.33 [−0.69 to 0.03] | Off vs. On −0.01 [−0.33 to 0.31]
Selnes, 2009^20^/ Prospective observational | 12 | CABG, on-pump | 23.2 (10.0); n=150 | 26.2 (10.2); n=123 | −3.00 [−5.41 to −0.59] | −0.30 [−0.54 to −0.06] | Off vs. NSC −0.22 [−0.56 to 0.12]
Selnes, 2009^20^/ Prospective observational | 12 | Non-surgical control | 23.2 (9.5); n=99 | 24.2 (9.6); n=91 | −1.00 [−3.72 to 1.72] | −0.10 [−0.39 to 0.18] | On vs. NSC −0.20 [−0.48 to 0.07]
Selnes, 2009^20^/ Prospective observational
Selnes, 2009^20^/ Prospective observational | 72 | CABG, off-pump | 22.9 (9.2); n=69 | 25.0 (10.3); n=43 | −2.10 [−5.87 to 1.67] | −0.22 [−0.60 to 0.17] | Off vs. On −0.20 [−0.56 to 0.16]
Selnes, 2009^20^/ Prospective observational | 72 | CABG, on-pump | 23.2 (10.0); n=150 | 23.3 (10.2); n=93 | −0.10 [−2.72 to 2.52] | −0.01 [−0.27 to 0.25] | Off vs. NSC −0.21 [−0.59 to 0.18]
Selnes, 2009^20^/ Prospective observational | 72 | Non-surgical control | 23.2 (9.5); n=99 | 23.3 (9.8); n=66 | −0.10 [−3.12 to 2.92] | −0.01 [−0.32 to 0.30] | On vs. NSC 0.00 [−0.32 to 0.32]

CI = confidence intervals; ES = effect size

Table 17 Mean change from baseline for [underlined: Boston Naming Test or Vocabulary WAIS III], CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Lee 2003^5^ / (Vocabulary WAIS III) Randomized trial | 12 | CABG, off-pump | 32.0 (13.8); n=30 | 29.7 (13.4); n=27 | 2.30 [−4.77 to 9.37] | 0.17 [−0.35 to 0.69] | 0.30 [−0.24 to 0.85]
Lee 2003^5^ / (Vocabulary WAIS III) Randomized trial | 12 | CABG, on-pump | 38.0 (14.5); n=30 | 39.9 (14.2); n=26 | −1.90 [−9.43 to 5.63] | −0.13 [−0.66 to 0.40]
Selnes, 2009^20^ / (Boston Naming Test) Prospective observational | 12 | CABG, off-pump | 26.0 (3.7); n=71 | 26.5 (3.7); n=55 | −0.50 [−1.80 to 0.80] | −0.13 [−0.49 to 0.22] | Off vs. On 0.12 [−0.20 to 0.44]
Selnes, 2009^20^ / (Boston Naming Test) Prospective observational | 12 | CABG, on-pump | 26.2 (3.7); n=152 | 27.1 (2.9); n=124 | −0.90 [−1.68 to -0.12] | −0.27 [−0.50 to -0.03] | Off vs. NSC 0.03 [−0.31 to 0.36]
Selnes, 2009^20^ / (Boston Naming Test) Prospective observational | 12 | Non-surgical control | 26.1 (3.6); n=99 | 26.7 (3.3); n=91 | −0.60 [−1.58 to 0.38] | −0.17 [−0.46 to 0.11] | On vs. NSC −0.09 [−0.36 to 0.18]
Selnes, 2009^20^ / (Boston Naming Test) Prospective observational
Selnes, 2009^20^ / (Boston Naming Test) Prospective observational | 72 | CABG, off-pump | 26.0 (3.7); n=71 | 26.3 (3.7); n=43 | −0.30 [−1.70 to 1.10] | −0.08 [−0.46 to 0.30] | Off vs. On −0.16 [−0.52 to 0.21]
Selnes, 2009^20^ / (Boston Naming Test) Prospective observational | 72 | CABG, on-pump | 26.2 (3.7); n=152 | 25.9 (4.0); n=95 | 0.30 [−0.70 to 1.30] | 0.08 [−0.18 to 0.33] | Off vs. NSC 0.03 [−0.35 to 0.41]
Selnes, 2009^20^ / (Boston Naming Test) Prospective observational | 72 | Non-surgical control | 26.1 (3.6); n=99 | 26.5 (3.0); n=67 | −0.40 [−1.41 to 0.61] | −0.12 [−0.43 to 0.19] | On vs. NSC 0.19 [−0.12 to 0.51]
Gold 1995^15^ / (Boston Naming Test) Randomized trial | 6 | CABG, low MAP | 24.6 (4.4); n=124 | NR | 0.4 (2.0); n=113 | NA | −0.19 [−0.45 to 0.08]
Gold 1995^15^ / (Boston Naming Test) Randomized trial | 6 | CABG, high MAP | 24.6 (4.6); n=124 | NR | 0.8 (2.3); n=112 | NA

CI = confidence intervals; ES = effect size; MAP = mean arterial pressure (during bypass); NSC = non-surgical control; WAIS = Wechsler Adult Intelligence Scale

Table 18 Mean change from baseline for [underlined: Mini Mental State Exam,] CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Kadoi 2003^27^ / Randomized trial | 6 | CABG, propofol | 46.4 (5.6); n=77 | 45.0 (5.9); n=77 | −1.40 [−3.22 to 0.42] | 0.24 [−0.07 to 0.56] | −0.03 [−0.35 to 0.28]
Kadoi 2003^27^ / Randomized trial | 6 | CABG, fentanyl | 47.7 (5.7); n=75 | 45.0 (6.4); n=75 | −2.70 [−4.64 to -0.76] | 0.44 [0.12 to 0.77]
Selnes 2009^20^ / Prospective observational | 72 | CABG, off-pump | 27.7 (2.0); n=75 | 28.5 (1.8); n=43 | −0.40 (1.6); n=43 | - | Off vs. On −0.13 [−0.51 to 0.26]
Selnes 2009^20^ / Prospective observational | 72 | CABG, on-pump | 27.6 (2.4); n=152 | 27.4 (2.5); n=96 | −0.22 (2.0); n=96 | - | Off vs. NSC −0.09 [−0.45 to 0.26]
Selnes 2009^20^ / Prospective observational | 72 | Non-surgical control | 27.9 (2.0); n=99 | 28.0 (2.3); n=67 | −0.12 (2.5); n=67 | - | On vs. NSC −0.04 [−0.36 to 0.27]

CI = confidence intervals; COWAT = Controlled Oral Word Association Test; ES = effect size; NSC = non-surgical control; SD = standard deviation

Table 19 Mean change from baseline for [underlined: Montreal Cognitive Assessment,] CABG studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Lamy 2013^1^ / Randomized trial | 12 | CABG, off-pump | 23.2 (4.4); n=1053 | NR | 0.4 (4.0); n=645 | NA | 0.02 [−0.08 to 0.13]
Lamy 2013^1^ / Randomized trial | 12 | CABG, on-pump | 23.2 (4.3); n=1028 | NR | 0.3 (4.0); n=628 | NA
Nathan 2001 7/ Randomized trial | 3 | CABG, hypothermic | NR | NR | NR | NA | No focal deficits were discovered in either group at any examination.
Nathan 2001 7/ Randomized trial | 3 | CABG, normothermic | NR | NR | NR | NA | No focal deficits were discovered in either group at any examination.

CI = confidence intervals; COWAT = Controlled Oral Word Association Test; ES = effect size; NSC = non-surgical control; SD = standard deviation

Table 20 Mean change from baseline for [underlined: Mini Mental State Exam,] CEA studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Baracchini 2012 22/ Prospective observational | 3 | CEA Group A, symptomatic | 27.4 (0.9); n=75 | 27.8 (0.9); n=75 | 0.40 [0.11 to 0.69] | −0.44 [−0.77 to -0.12] | Group A vs. Lap. 0.39 [0.06 to 0.72]
Baracchini 2012 22/ Prospective observational | 3 | CEA Group B, asymptomatic | 27.8 (1.0); n=70 | 28.0 (1.1); n=70 | 0.20 [−0.15 to 0.55] | −0.19 [−0.52 to 0.14] | Group B vs. Lap. 0.22 [−0.12 to 0.55]
Baracchini 2012 22/ Prospective observational | 3 | . Laparoscopic Cholecystectomy | 28.2 (1.5); n=68 | 28.1 (1.7); n=68 | −0.10 [−0.64 to 0.44] | 0.06 [−0.27 to 0.40] | Group A vs. B 0.20 [−0.13 to 0.53]
Baracchini 2012 22/ Prospective observational
Baracchini 2012 22/ Prospective observational | 12 | CEA Group A, symptomatic | 27.4 (0.9); n=75 | 27.7 (0.8); n=75 | 0.30 [0.03 to 0.57] | −0.35 [−0.67 to -0.03] | Group A vs. Lap. 0.26 [−0.07 to 0.59]
Baracchini 2012 22/ Prospective observational | 12 | CEA Group B, asymptomatic | 27.8 (1.0); n=70 | 28.0 (1.1); n=70 | 0.20 [−0.15 to 0.55] | −0.19 [−0.52 to 0.14] | Group B vs. Lap. 0.16 [−0.17 to 0.50]
Baracchini 2012 22/ Prospective observational | 12 | . Laparoscopic Cholecystectomy | 28.2 (1.5); n=68 | 28.2 (1.2); n=68 | 0.00 [−0.46 to 0.46] | 0.00 [−0.34 to 0.34] | Group A vs. B 0.10 [−0.22 to 0.43]

CI = confidence intervals; COWAT = Controlled Oral Word Association Test; ES = effect size; NSC = non-surgical control; SD = standard deviation

Table 21 Mean change from baseline for the [underlined: Montreal Cognitive Assessment], CEA studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Baracchini 2012^22^/ Prospective observational | 3 | CEA Group A, symptomatic | 26.0 (2.0); n=75 | 26.9 (1.7); n=75 | 0.90 [0.31 to 1.49] | −0.48 [−0.81 to −0.16] | Group A vs. Lap 0.52 [0.19 to 0.85]
Baracchini 2012^22^/ Prospective observational | 3 | CEA Group B, asymptomatic | 26.8 (1.7); n=70 | 27.1 (1.3); n=70 | 0.30 [−0.20 to 0.80] | −0.20 [−0.53 to 0.13] | Group B vs. Lap. 0.20 [−0.14 to 0.53]
Baracchini 2012^22^/ Prospective observational | 3 | . Laparoscopic Cholecystectomy | 27.1 (1.4); n=68 | 27.1 (1.7); n=68 | 0.00 [−0.52 to 0.52] | 0.00 [−0.34 to 0.34] | Group A vs. B 0.35 [0.02 to 0.68]
Baracchini 2012^22^/ Prospective observational
Baracchini 2012^22^/ Prospective observational | 12 | CEA Group A, symptomatic | 26.0 (2.0); n=75 | 27.0 (1.1); n=75 | 1.00 [0.48 to 1.52] | −0.62 [−0.94 to −0.29] | Group A vs. Lap. 0.58 [0.24 to 0.91]
Baracchini 2012^22^/ Prospective observational | 12 | CEA Group B, asymptomatic | 26.8 (1.7); n=70 | 27.2 (1.8); n=70 | 0.40 [−0.18 to 0.98] | −0.23 [−0.56 to 0.11] | Group B vs. Lap. 0.19 [−0.15 to 0.52]
Baracchini 2012^22^/ Prospective observational | 12 | . Laparoscopic Cholecystectomy | 27.1 (1.4); n=68 | 27.2 (1.5); n=68 | 0.10 [−0.39 to 0.59] | −0.07 [−0.40 to 0.27] | Group A vs. B 0.36 [0.03 to 0.69]

CI = confidence intervals; COWAT = Controlled Oral Word Association Test; ES = effect size; NSC = non-surgical control; SD = standard deviation

Table 22 Mean change from baseline for [underlined: Mini Mental State Exam,] AVR studies. Higher scores indicate a better result

Study / Design | Follow-up (mos) | Intervention | Score at Baseline (SD); n | Score at Followup (SD); n | Mean change from baseline (SD); n or [95%CI] | ES [95%CI] within groups | ES [95%CI] between groups
Fakin 2011^18^/ Randomized trial | 4 | AVR, hypothermic | NR, “normal” | NR | NR | | “Both patient groups scored normal throughout the whole study period (ranging from 29 to 30 points). This indicated that all patients were without an overt clinically relevant cognitive impairment at all points of measurement.”
Fakin 2011^18^/ Randomized trial | 4 | AVR, normothermic | NR, “normal” | NR | NR

CI = confidence intervals; COWAT = Controlled Oral Word Association Test; ES = effect size; NSC = non-surgical control; SD = standard deviation

* “Both patient groups scored normal throughout the whole study period (ranging from 29 to 30 points). This indicated that all patients were without an overt clinically relevant cognitive impairment at all points of measurement.”

Table 23 Mean change from baseline for [underlined: domains from Altinbas 2011]: CAS versus CEA

Study / Design | Follow-up (mos) | Domain | Mean change from baseline z score (SD); n CAS | Mean change from baseline z score (SD); n CEA | Mean difference [95%CI] between groups
Altinbas, 2011^16^/ Randomized trial | 6 | Attention | −0.09 (1.05); n=59 | −0.13 (1.60); n=57 | 0.04 [−0.46 to 0.53]
Altinbas, 2011^16^/ Randomized trial | 6 | Executive | 0.13 (0.36); n=55 | 0.17 (0.48); n=45 | −0.05 [−0.21 to 0.12]
Altinbas, 2011^16^/ Randomized trial | 6 | Language | −0.25 (0.68); n=59 | −0.18 (0.70); n=58 | −0.07 [−0.32 to 0.18]
Altinbas, 2011^16^/ Randomized trial | 6 | Verbal memory | −0.16 (0.76); n=59 | −0.09 (1.00); n=56 | −0.07 [−0.39 to 0.26]
Altinbas, 2011^16^/ Randomized trial | 6 | Visual memory | 0.24 (0.72); n=53 | 0.24 (0.66); n=52 | 0.00 [−0.27 to 0.26]
Altinbas, 2011^16^/ Randomized trial | 6 | Visual perception | −0.14 (0.54); n=54 | −0.17 (0.73); n=50 | 0.04 [−0.21 to 0.28]

CI = confidence intervals; ES = effect size; SD = standard deviation;

## References

1 Lamy A, Devereaux PJ, Prabhakaran D, et al. Effects of off-pump and on-pump coronary-artery bypass grafting at 1 year. N Engl J Med. Mar. 28. 2013;368(13):1179-1188. [pmid: 23477676].
2 Jensen BO, Rasmussen LS, Steinbruchel DA. Cognitive outcomes in elderly high-risk patients 1 year after off-pump versus on-pump coronary artery bypass grafting. A randomized trial. Eur J Cardiothorac Surg. Nov. 2008;34(5):1016-1021. [pmid: 18778948].
3 Vedin J, Nyman H, Ericsson A, et al. Cognitive function after on or off pump coronary artery bypass grafting. Eur J Cardiothorac Surg. Aug. 2006;30(2):305-310. [pmid: 16828295].
4 Lund C, Sundet K, Tennoe B, et al. Cerebral ischemic injury and cognitive impairment after off-pump and on-pump coronary artery bypass grafting surgery. Ann Thorac Surg. Dec. 2005;80(6):2126-2131. [pmid: 16305857].
5 Lee JD, Lee SJ, Tsushima WT, et al. Benefits of off-pump bypass on neurologic and clinical morbidity: a prospective randomized trial. Ann Thorac Surg. Jul. 2003;76(1):18-25. discussion-6. [pmid: 12842506].
6 Boodhwani M, Rubens F, Wozny D, et al. Effects of sustained mild hypothermia on neurocognitive function after coronary artery bypass surgery: a randomized, double-blind study. J Thorac Cardiovasc Surg. Dec. 2007;134(6):1443-1450. discussion 51–2. [pmid: 18023662].
7 Nathan HJ, Wells GA, Munson JL, et al. Neuroprotective effect of mild hypothermia in patients undergoing coronary artery surgery with cardiopulmonary bypass: a randomized trial. Circulation. Sep. 18. Suppl 1. 2001;104(12):I85-I91. [pmid: 11568036].
8 Nathan HJ, Rodriguez R, Wozny D, et al. Neuroprotective effect of mild hypothermia in patients undergoing coronary artery surgery with cardiopulmonary bypass: five-year follow-up of a randomized trial. J Thorac Cardiovasc Surg. May. 2007;133(5):1206-1211. [pmid: 17467430].
9 Djaiani G, Katznelson R, Fedorko L, et al. Early benefit of preserved cognitive function is not sustained at one-year after cardiac surgery: a longitudinal follow-up of the randomized controlled trial. Can J Anaesth. May. 2012;59(5):449-455. [pmid: 22290354].
10 Anastasiadis K, Antonitsis P, Papakonstantinou C. When is the optimal time to perform neurocognitive assessment after coronary artery bypass surgery?. Ann Thorac Surg. Nov. 2011;92(5):1933. author reply-4. [pmid: 22051305].
11 Flesch M, Knipp S, Kessler G, et al. ARTA: AT1-receptor blocker therapy in patients undergoing coronary artery bypass grafting. Clin Res Cardiol. Jan. 2009;98(1):33-43. [pmid: 18853093].
12 Silbert BS, Scott DA, Evered LA, et al. A comparison of the effect of high- and low-dose fentanyl on the incidence of postoperative cognitive dysfunction after coronary artery bypass surgery in the elderly. Anesthesiology. Jun. 2006;104(6):1137-1145. [pmid: 16732083].
13 Alex J, Laden G, Cale AR, et al. Pretreatment with hyperbaric oxygen and its effect on neuropsychometric dysfunction and systemic inflammatory response after cardiopulmonary bypass: a prospective randomized double-blind trial. J Thorac Cardiovasc Surg. Dec. 2005;130(6):1623-1630. [pmid: 16308008].
14 Kadoi Y, Kawauchi C, Ide M, et al. Preoperative depression is a risk factor for postoperative short-term and long-term cognitive dysfunction in patients with diabetes mellitus. J Anesth. Feb. 2011;25(1):10-17. [pmid: 21161290].
15 Gold JP, Charlson ME, Williams-Russo P, et al. Improvement of outcomes after coronary artery bypass. A randomized trial comparing intraoperative high versus low mean arterial pressure. J Thorac Cardiovasc Surg. Nov. 1995;110(5):1302-1311. discussion 11–4. [pmid: 7475182].
16 Altinbas A, van Zandvoort MJ, van den Berg E, et al. Cognition after carotid endarterectomy or stenting: a randomized comparison. Neurology. Sep. 13. 2011;77(11):1084-1090. [pmid: 21880992].
17 Crawley F, Stygall J, Lunn S, et al. Comparison of microembolism detected by transcranial Doppler and neuropsychological sequelae of carotid surgery and percutaneous transluminal angioplasty. Stroke. Jun. 2000;31(6):1329-1334. [pmid: 10835452].
18 Fakin R, Zimpfer D, Sodeck GH, et al. Influence of temperature management on neurocognitive function in biological aortic valve replacement. A prospective randomized trial. J Cardiovasc Surg (Torino). Feb. 2012;53(1):107-112. [pmid: 22231536].
19 McKhann GM, Selnes OA, Grega MA, et al. Subjective memory symptoms in surgical and nonsurgical coronary artery patients: 6-year follow-up. Ann Thorac Surg. Jan. 2009;87(1):27-34. [pmid: 19101263].
20 Selnes OA, Grega MA, Bailey MM, et al. Do management strategies for coronary artery disease influence 6-year cognitive outcomes?. Ann Thorac Surg. Aug. 2009;88(2):445-454. [pmid: 19632391].
21 Andrew MJ, Baker RA, Bennetts J, et al. A comparison of neuropsychologic deficits after extracardiac and intracaradiac surgery. J Cardiothorac Vasc Anesth. Feb. 2001;15(1):9-14. [pmid: 11254832].
22 Baracchini C, Mazzalai F, Gruppo M, et al. Carotid endarterectomy protects elderly patients from cognitive decline: a prospective study. Surgery. Jan. 2012;151(1):99-106. [pmid: 21943640].
23 Knipp SC, Kahlert P, Jokisch D, et al. Cognitive function after transapical aortic valve implantation: a single-centre study with 3-month follow-up. Interact Cardiovasc Thorac Surg. Feb. 2013;16(2):116-122. [pmid: 23148084].
24 Jensen BO, Hughes P, Rasmussen LS, et al. Cognitive outcomes in elderly high-risk patients after off-pump versus conventional coronary artery bypass grafting: a randomized trial. Circulation. Jun. 20. 2006;113(24):2790-2795. [pmid: 16769915].
25 Selnes OA, Zeger SL. Coronary artery bypass grafting baseline cognitive assessment: essential not optional. Ann Thorac Surg. Feb. 2007;83(2):374-376. [pmid: 17257951].
26 Selnes OA, Grega MA, Borowicz LM Jr, et al. Cognitive outcomes three years after coronary artery bypass surgery: a comparison of on-pump coronary artery bypass graft surgery and nonsurgical controls. Ann Thorac Surg. Apr. 2005;79(4):1201-1209. [pmid: 15797050].
27 Kadoi Y, Saito S, Kunimoto F, et al. Comparative effects of propofol versus fentanyl on cerebral oxygenation state during normothermic cardiopulmonary bypass and postoperative cognitive dysfunction. Annals of Thoracic Surgery. Mar. 2003;75(3):840-846. [pmid: 12645704].
28 McKhann GM, Grega MA, Borowicz LM Jr, et al. Is there cognitive decline 1 year after CABG? Comparison with surgical and nonsurgical controls. Neurology. Oct. 11. 2005;65(7):991-999. [pmid: 16107605].