# Strength of Evidence

Appendix L. Table 1 Strength of Evidence - CABG

Comparison | Outcome | Study design: No. studies (N) | Study Limitations | Consistency | Precision | Directness | SOE Grade*: Finding
Off-pump CABG vs. On-pump CABG | Clinical Outcomes (Dementia, CI) | RCT: 5 (5126) OBS: 1 (326) | RCT: Medium OBS: High | - | - | - | Insufficient; No evidence for this outcome
Off-pump CABG vs. On-pump CABG | Composite NP test “impairment” | RCT: 4 (374) | Medium | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; No evidence for this outcome
Off-pump CABG vs. On-pump CABG | NP tests, Attention | RCT: 3 (250) OBS: 1 (326) | RCT: MediumOBS: High | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. On-pump CABG | NP tests, Memory | RCT: 4 (374) OBS: 1 (326) | RCT: Medium OBS: High | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. On-pump CABG | NP tests, Language | RCT: 3 (250) OBS: 1 (326) | RCT: MediumOBS: High | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. On-pump CABG | NP tests, Executive | RCT: 5 (1420) OBS: 1 (326) | RCT: Medium OBS: High | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. On-pump CABG | NP tests, VSF | RCT: 2 (190) OBS: 1 (326) | RCT: MediumOBS: High | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. On-pump CABG | NP tests, Psychomotor speed | RCT: 2 (180) OBS: 1 (326) | RCT: Medium OBS: High | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. On-pump CABG | Neuropsychological tests, global cognitive screen | RCT: 1 (1273) OBS: 1 (326) | RCT: Medium OBS: High | Consistent | Imprecise | Direct | RCT: Low; No statistically significant differences OBS: Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. Non-surgical control | Clinical Outcomes (Dementia, CI) | OBS: 1 (251) | High | - | - | - | Insufficient; No evidence for this outcome
On-pump CABG vs. Non-surgical control | Composite NP test “impairment” | OBS: 1 (251) | High | - | - | - | Insufficient; No evidence for this outcome
On-pump CABG vs. Non-surgical control | NP tests, Attention | OBS: 1 (251) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. Non-surgical control | NP tests, Memory | OBS: 1 (251) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. Non-surgical control | NP tests, Language | OBS: 1 (251) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. Non-surgical control | NP tests, Executive | OBS: 1 (251) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. Non-surgical control | NP tests, VSF | OBS: 1 (251) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. Non-surgical control | NP tests, Psychomotor speed | OBS: 1 (251) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. Non-surgical control | Neuropsychological tests, global cognitive screen | OBS: 1 (251) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. Non-surgical control | Clinical Outcomes (Dementia, CI) | OBS: 1 (174) | High | - | - | - | Insufficient; No evidence for this outcome
Off-pump CABG vs. Non-surgical control | Composite NP test “impairment” | OBS: 1 (174) | High | - | - | - | Insufficient; No evidence for this outcome
Off-pump CABG vs. Non-surgical control | NP tests, Attention | OBS: 1 (174) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. Non-surgical control | NP tests, Memory | OBS: 1 (174) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. Non-surgical control | NP tests, Language | OBS: 1 (174) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. Non-surgical control | NP tests, Executive | OBS: 1 (174) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. Non-surgical control | NP tests, VSF | OBS: 1 (174) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. Non-surgical control | NP tests, Psychomotor speed | OBS: 1 (174) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Off-pump CABG vs. Non-surgical control | Neuropsychological tests, global cognitive screen | OBS: 1 (174) | High | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | Clinical Outcomes (Dementia, CI) | RCT: 1 (64) | Medium | - | - | - | Insufficient; No evidence for this outcome
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | Composite NP test “impairment” | RCT: 1 (64) | Medium | Unknown | Precise | Direct | Low; Reduced risk (21 vs. 61%; RR=0.34 [CI, 0.16 to 0.73])
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | NP tests, Attention | RCT: 1 (64) | Medium | Unknown | Precise | Direct | Low; MECC group scored statistically significantly better on WAIS digit symbol ES=1.08 [CI, 0.53 to 1.62]
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | NP tests, Memory | RCT: 1 (64) | Medium | Unknown | Precise | Direct | Low; MECC group scored statistically significantly better on Fuld object memory evaluation.
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | NP tests, Language | RCT: 1 (64) | Medium | - | - | - | Insufficient; No evidence for this outcome
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | NP tests, Executive | RCT: 1 (64) | Medium | Unknown | Precise | Direct | Low, minimal extracorporeal bypass group scored statistically significantly better on Stroop Color/Word ES=0.89 [CI,0.36 to 1.42] WAIS digit span backward ES=0.94 [CI, 0.41 to 1.48]; WAIS digit symbol ES=1.08 [CI, 0.53 to 1.62]
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | NP tests, VSF | RCT: 1 (64) | Medium | Unknown | Precise | Direct | Low, minimal extracorporeal bypass group scored statistically significantly better on Judgment of Line Orientation ES=0.98 [CI, 0.44 to 1.52]
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | NP tests, Psychomotor speed | RCT: 1 (64) | Medium | Unknown | Precise | Direct | Low, minimal extracorporeal bypass group scored statistically significantly better on WAIS digit span backward ES=0.94 [CI, 0.41 to 1.48]; WAIS digit symbol ES=1.08 [CI, 0.53 to 1.62]
On-pump CABG vs. CABG with Minimal Extracorporeal Bypass (MECC)10 | Neuropsychological tests, global cognitive screen | RCT: 1 (64) | Medium | - | - | - | Insufficient; No evidence for this outcome
Hypothermic vs. Normothermic4, 6, 7 | Clinical Outcomes (Dementia, CI) | RCT: 3 (610) | Medium | - | - | - | Insufficient; No evidence for this outcome
Hypothermic vs. Normothermic4, 6, 7 | Composite NP test “impairment” | RCT: 3 (610) | Medium | Consistent | Imprecise | Direct | Low; No statistically significant differences
Hypothermic vs. Normothermic4, 6, 7 | NP tests, Attention | RCT: 3 (610) | Medium | Consistent | Imprecise | Direct | Low; No statistically significant differences
Hypothermic vs. Normothermic4, 6, 7 | NP tests, Memory | RCT: 2 (387) | Medium | Consistent | Imprecise | Direct | Low; No statistically significant differences
Hypothermic vs. Normothermic4, 6, 7 | NP tests, Language | RCT: 2 (387) | Medium | Consistent | Precise | Direct | Moderate; No statistically significant differences
Hypothermic vs. Normothermic4, 6, 7 | NP tests, Executive | RCT: 3 (610) | Medium | Consistent | Precise | Direct | Moderate; No statistically significant differences
Hypothermic vs. Normothermic4, 6, 7 | NP tests, VSF | RCT: 1 (120) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Hypothermic vs. Normothermic4, 6, 7 | NP tests, Psychomotor speed | RCT: 3 (610) | Medium | Consistent | Precise | Direct | Moderate; No statistically significant differences
Hypothermic vs. Normothermic4, 6, 7 | Neuropsychological tests, global cognitive screen | | - | - | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | Clinical Outcomes (Dementia, CI) | RCT: 1 (350) | Medium | - | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | Composite NP test “impairment” | RCT: 1 (350) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | NP tests, Attention | RCT: 1 (350)) | Medium | Unknown | Precise | Direct | Low; Evidence has unacceptable deficiencies
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | NP tests, Memory | RCT: 1 (350) | Medium | Unknown | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | NP tests, Language | RCT: 1 (350) | Medium | Unknown | Precise | Direct | Low; Evidence has unacceptable deficiencies
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | NP tests, Executive | RCT: 1 (350) | Medium | Unknown | Precise | Direct | Low; Evidence has unacceptable deficiencies
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | NP tests, VSF | - | Medium | - | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | NP tests, Psychomotor speed | RCT: 1 (350) | Medium | Unknown | Precise | Direct | Low; Evidence has unacceptable deficiencies
Anesthetic Regimen, High- vs. Low-dose Fentanyl12, | Neuropsychological tests, global cognitive screen | RCT: 1 (350) | Medium | - | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, Propofol vs. Fentanyl27 | Clinical Outcomes (Dementia, CI) | RCT: 1 (180) | Medium | - | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, Propofol vs. Fentanyl27 | Composite NP test “impairment” | RCT: 1 (180) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Anesthetic Regimen, Propofol vs. Fentanyl27 | NP tests, Attention | RCT: 1 (180)) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Anesthetic Regimen, Propofol vs. Fentanyl27 | NP tests, Memory | RCT: 1 (180) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Anesthetic Regimen, Propofol vs. Fentanyl27 | NP tests, Language | - | Medium | - | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, Propofol vs. Fentanyl27 | NP tests, Executive | RCT: 1 (180)) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Anesthetic Regimen, Propofol vs. Fentanyl27 | NP tests, VSF | - | Medium | - | - | - | Insufficient; No evidence for this outcome
Anesthetic Regimen, Propofol vs. Fentanyl27 | NP tests, Psychomotor speed | RCT: 1 (180) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Anesthetic Regimen, Propofol vs. Fentanyl27 | Neuropsychological tests, global cognitive screen | RCT: 1 (180) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | Clinical Outcomes (Dementia, CI) | RCT: 1 (64) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | Composite NP test “impairment” | RCT: 1 (64) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | NP tests, Attention | RCT: 1 (64) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | NP tests, Memory | RCT: 1 (64) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | NP tests, Language | RCT: 1 (64) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | NP tests, Executive | RCT: 1 (64) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | NP tests, VSF | RCT: 1 (64) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | NP tests, Psychomotor speed | RCT: 1 (64) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Atmospheric Oxygen vs. Hyperbaric Oxygen13 | Neuropsychological tests, global cognitive screen | RCT: 1 (64) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | Clinical Outcomes (Dementia, CI) | RCT: 1 (226) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | Composite NP test “impairment” | RCT: 1 (226) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | NP tests, Attention | RCT: 1 (226) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | NP tests, Memory | RCT: 1 (226) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | NP tests, Language | RCT: 1 (226) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | NP tests, Executive | RCT: 1 (226) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | NP tests, VSF | RCT: 1 (226) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | NP tests, Psychomotor speed | RCT: 1 (226) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Cell Saver vs. Cardiotomy Suction9 | Neuropsychological tests, global cognitive screen | RCT: 1 (226) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | Clinical Outcomes (Dementia, CI) | RCT: 1 (248) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | Composite NP test “impairment” | RCT: 1 (248) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | NP tests, Attention | RCT: 1 (248) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | NP tests, Memory | RCT: 1 (248) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | NP tests, Language | RCT: 1 (248) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | NP tests, Executive | RCT: 1 (248) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | NP tests, VSF | RCT: 1 (248) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | NP tests, Psychomotor speed | RCT: 1 (248) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, High Arterial Blood Pressure vs. Low Arterial Blood Pressure15 | Neuropsychological tests, global cognitive screen | RCT: 1 (248) | Medium | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | Clinical Outcomes (Dementia, CI) | RCT: 1 (106) | Unclear | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | Composite NP test “impairment” | RCT: 1 (106) | Unclear | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | NP tests, Attention | RCT: 1 (106) | Unclear | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | NP tests, Memory | RCT: 1 (106) | Unclear | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | NP tests, Language | RCT: 1 (106) | Unclear | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | NP tests, Executive | RCT: 1 (106) | Unclear | Unknown | Precise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | NP tests, VSF | RCT: 1 (106) | Unclear | - | - | - | Insufficient; No evidence for this outcome
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | NP tests, Psychomotor speed | RCT: 1 (106) | Unclear | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
Miscellaneous Procedure Methods, Candesartan (preoperative) vs. Placebo (preoperative)11 | Neuropsychological tests, global cognitive screen | RCT: 1 (106) | Unclear | - | - | - | Insufficient; No evidence for this outcome
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | Clinical Outcomes (Dementia, CI) | OBS: 1 (109) | High | - | - | - | Insufficient; No evidence for this outcome
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | Composite NP test “impairment” | OBS: 1 (109) | High | - | - | - | Insufficient; No evidence for this outcome
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | NP tests, Attention | OBS: 1 (109) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | NP tests, Memory | OBS: 1 (109) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | NP tests, Language | OBS: 1 (109) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | NP tests, Executive | OBS: 1 (109) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | NP tests, VSF | OBS: 1 (109) | High | - | - | - | Insufficient; No evidence for this outcome
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | NP tests, Psychomotor speed | OBS: 1 (109) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CABG vs. Aortic or Mitral Valve Surgery Alone or in Combination with CABG21 | Neuropsychological tests, global cognitive screen | OBS: 1 (109) | High | - | - | - | Insufficient; No evidence for this outcome

Appendix L. Table 2 Strength of Evidence – AVR

Comparison | Outcome | Study design: No. studies (N) | Study Limitations | Consistency | Precision | Directness | SOE Grade^*^: Finding
AVR under hypothermia vs. AVR under normothermia18 | Clinical Outcomes (Dementia, CI) | RCT: 1 (60) | Medium | - | - | - | Insufficient; No evidence for this outcome
AVR under hypothermia vs. AVR under normothermia18 | Composite NP test “impairment” | RCT: 1 (60) | Medium | - | - | - | Insufficient; No evidence for this outcome
AVR under hypothermia vs. AVR under normothermia18 | Neuropsychological tests, Attention | RCT: 1 (60) | Medium | Unknown | Unclear^**^ | Direct | Insufficient; Evidence has unacceptable deficiencies
AVR under hypothermia vs. AVR under normothermia18 | Neuropsychological tests, Memory | - | Medium | - | - | - | Insufficient; No evidence for this outcome
AVR under hypothermia vs. AVR under normothermia18 | Neuropsychological tests, Language | - | Medium | - | - | - | Insufficient; No evidence for this outcome
AVR under hypothermia vs. AVR under normothermia18 | Neuropsychological tests, Executive | RCT: 1 (60) | Medium | Unknown | Unclear^**^ | Direct | Insufficient; Evidence has unacceptable deficiencies
AVR under hypothermia vs. AVR under normothermia18 | Neuropsychological tests, VSF | - | Medium | - | - | - | Insufficient; No evidence for this outcome
AVR under hypothermia vs. AVR under normothermia18 | Neuropsychological tests, Psychomotor speed | | Medium | - | - | - | Insufficient; No evidence for this outcome
AVR under hypothermia vs. AVR under normothermia18 | Neuropsychological tests, global cognitive screen | RCT: 1 (60) | Medium | Unknown | Unclear^**^ | Direct | Insufficient; Evidence has unacceptable deficiencies
AVR vs. Transapical transcatheter aortic valve implantation | Clinical Outcomes (Dementia, CI) | OBS: 1 (64) | High | - | - | - | Insufficient; No evidence for this outcome
AVR vs. Transapical transcatheter aortic valve implantation | Composite NP test “impairment” | OBS: 1 (64) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
AVR vs. Transapical transcatheter aortic valve implantation | Neuropsychological tests, Attention | | | - | - | - | Insufficient; No evidence for this outcome
AVR vs. Transapical transcatheter aortic valve implantation | Neuropsychological tests, Memory | | | - | - | - | Insufficient; No evidence for this outcome
AVR vs. Transapical transcatheter aortic valve implantation | Neuropsychological tests, Language | | | - | - | - | Insufficient; No evidence for this outcome
AVR vs. Transapical transcatheter aortic valve implantation | Neuropsychological tests, Executive | | | - | - | - | Insufficient; No evidence for this outcome
AVR vs. Transapical transcatheter aortic valve implantation | Neuropsychological tests, VSF | | | - | - | - | Insufficient; No evidence for this outcome
AVR vs. Transapical transcatheter aortic valve implantation | Neuropsychological tests, Psychomotor speed | | | - | - | - | Insufficient; No evidence for this outcome
AVR vs. Transapical transcatheter aortic valve implantation | Neuropsychological tests, global cognitive screen | | | - | - | - | Insufficient; No evidence for this outcome

CAS = Carotid artery stenting; CEA = Carotid endarterectomy; CI = cognitive impairment; OBS = prospective observational cohort study; RCT = randomized controlled trial; VSF = visual-spatial functioning

* Strength of the evidence was evaluated based on the following domains: (1) study limitations (risk of bias or internal validity); (2) directness; (3) consistency; (4) precision; and, when appropriate, (5) reporting bias. Study limitations will be rated as low, medium or high based on the study design and risk of bias of individual studies.

** Though the Fakin study reports that they collected Trails A, Trails B and MMSE at baseline and follow-up, the study reported insufficient detail on these results quantify within or between-group changes in these outcomes. Precision could not be determined.

Appendix L. Table 3 Strength of Evidence for CAS / CEA studies

Comparison | Outcome | Study design: No. studies (N) | Study Limitations | Consistency | Precision | Directness | SOE Grade^*^: Finding
CEA vs. CAS16 | Clinical Outcomes (Dementia, CI) | RCT: 1 (177) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. CAS16 | Composite NP test “impairment” | RCT: 1 (177) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. CAS16 | Neuropsychological tests, Attention | RCT: 1 (177) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CEA vs. CAS16 | Neuropsychological tests, Memory | RCT: 1 (177) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
CEA vs. CAS16 | Neuropsychological tests, Language | RCT: 1 (177) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
CEA vs. CAS16 | Neuropsychological tests, Executive | RCT: 1 (177) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
CEA vs. CAS16 | Neuropsychological tests, VSF | RCT: 1 (177) | Medium | Unknown | Precise | Direct | Low; No statistically significant differences
CEA vs. CAS16 | Neuropsychological tests, Psychomotor speed | RCT: 1 (177) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. CAS16 | Neuropsychological tests, global cognitive screen | RCT: 1 (177) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. Angioplasty17 | Clinical Outcomes (Dementia, CI) | RCT: 1 (46) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. Angioplasty17 | Composite NP test “impairment” | | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CEA vs. Angioplasty17 | Neuropsychological tests, Attention | RCT: 1 (46) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CEA vs. Angioplasty17 | Neuropsychological tests, Memory | RCT: 1 (46) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CEA vs. Angioplasty17 | Neuropsychological tests, Language | RCT: 1 (46) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. Angioplasty17 | Neuropsychological tests, Executive | RCT: 1 (46) | Medium | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CEA vs. Angioplasty17 | Neuropsychological tests, VSF | RCT: 1 (46) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. Angioplasty17 | Neuropsychological tests, Psychomotor speed | RCT: 1 (46) | Medium | Consistent | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies
CEA vs. Angioplasty17 | Neuropsychological tests, global cognitive screen | RCT: 1 (46) | Medium | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Clinical Outcomes (Dementia, CI) | OBS: 1 (227) | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Composite NP test “impairment” | | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Neuropsychological tests, Attention | - | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Neuropsychological tests, Memory | - | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Neuropsychological tests, Language | - | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Neuropsychological tests, Executive | - | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Neuropsychological tests, VSF | - | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Neuropsychological tests, Psychomotor speed | - | High | - | - | - | Insufficient; No evidence for this outcome
CEA vs. laparoscopic cholecystectomy control22 | Neuropsychological tests, global cognitive screen | OBS: 1 (227) | High | Unknown | Imprecise | Direct | Insufficient; Evidence has unacceptable deficiencies

* Strength of the evidence was evaluated based on the following domains: (1) study limitations (risk of bias or internal validity); (2) directness; (3) consistency; (4) precision; and, when appropriate, (5) reporting bias. Study limitations will be rated as low, medium or high based on the study design and risk of bias of individual studies.

CAS = Carotid artery stenting; CEA = Carotid endarterectomy; CI = cognitive impairment; OBS = prospective observational cohort study; RCT = randomized controlled trial; VSF = visual-spatial functioning