# Stroke/TIA Outcomes Tables

Appendix K. Table 1 Stroke / TIA Outcomes - CABG

Study/Design | Stroke n/N (%) | | TIA n/N (%)
Study/Design | Intervention | Control | Intervention | Control
Lamy, 2013^1^ RCT | Off-pump CABG 36/2375 (1.5); 1 year | CABG 40/2377 (1.7); 1 year | Off-pump CABG NR | CABG NR
Jensen, 2006;^24^ 2008^2^ RCT | Off-pump CABG 1/61 (1.6); 3 mos. | CABG 1/59 (1.7); 3 mos. | Off-pump CABG NR | CABG NR
Vedin, 2006^3^ RCT | Off-pump CABG 0/33 | CABG 0/37 | Off-pump CABG 0/33 | CABG 0/37
Lund, 2005^4^ RCT | Off-pump CABG NR | CABG NR | Off-pump CABG NR | CABG NR
Lee, 2003^5^ RCT | Off-pump CABG 0/30 | CABG 1/30 (3.3) Detected by scan | Off-pump CABG NR | CABG NR
Boodhwani, 2007^6^ RCT | NR | NR | NR | NR
McKhann, 2005;^28^ Selnes 2009^20^ Prospective | Off-pump CABG NR at 3 and 12 mos.; 4% at 72 mos. | Non-surgical control NR at 3 and 12 mos.; 3% at 72 mos. | Off-pump CABG NR at 3 and 12 mos. 3% at 72 mos. | Non-surgical control NR at 3 and 12 mos. 4% at 72 mos.
Nathan, 2001;^7^ 2007^8^ RCT | NR | NR | NR | NR
Djaiani, 2012^9^ RCT | NR | NR | NR | NR
Anastasiadis, 2011^10^ RCT | MECC 0/32 | CECC 0/32 | MECC 0/32 | CECC 0/32
Flesch, 2009^11^ RCT | Candesartan 2/43 (4.7%) | Placebo 5/44 (11.4%) | NR | NR
Silbet, 2006^12^ RCT | 2 post-procedure strokes (NR by group) | | NR | NR
Alex, 2005^13^ RCT | NR | NR | NR | NR
Kadoi, 2003^27^ RCT | Propofol 3/90 (3.3%) | Fentanyl (3/90) (3.3%) | NR | NR
Gold, 1995^15^ RCT | NR | NR | NR | NR
Andrew, 2001^21^ Prospective | NR | NR | NR | NR

CABG = coronary artery bypass grafting; NR = not reported; TIA = transient ischemic attack; MECC = minimal extracorporeal circulation; CECC = conventional extracorporeal circulation

Appendix K. Table 2 Stroke/TIA Outcomes Tables - AVR

| Stroke | | TIA
Study | Intervention | Control | Intervention | Control
Knipp, 2013^23^ | AVR 1/37 (2.7) | TA-TAVI 1 (fatal) /27 (3.7) | NR | NR
Fakin, 2012^18^ | 0 (0) | 0 (0) | NR | NR
Andrew, 2001^21^ | NR | NR | NR | NR

CABG = coronary artery bypass grafting; NR = not reported; TIA = transient ischemic attack; TA-TAVI = transapical transcatheter aortic valve implantation

Appendix K. Table 3 Stroke/TIA Outcomes Tables – CAS and CEA

| Stroke | | TIA
Study | Intervention | Control | Intervention | Control
Altinbas, 2011^16^ CAS (n=71) vs CEA (n=69) RCT | 6 months: There were no significant differences between CAS and CEA in the 6-month stroke rate (data were not shown). | | NR | NR
Baracchini, 2012^22^ Prospective observational cohort study | 30 days: Symptomatic 0/75 (0) | 30 days: Asymptomatic 0/70 (0) | 30 days: Symptomatic 3/75 (4%) | At 30 days: Asymptomatic 0/70 (0)
Crawley, 2000^17^ Carotid PTA (n=20) vs CEA (n=26) RCT | NR | NR | NR | NR

asx=asymptomatic; CABG = coronary artery bypass grafting; NR = not reported; RCT=randomized controlled trial; TIA = transient ischemic attackasx=asymptomatic; CABG = coronary artery bypass grafting; NR = not reported; RCT=randomized controlled trial; TIA = transient ischemic attack;