# Cognitive Outcomes Tables: Individual Neuropsychological Tests/Cognitive Domains

Appendix J. Table 1 Cognitive Outcomes Tables: Individual Neuropsychological Tests/Cognitive Domains - CABG

Appendix J. Table 2 Cognitive Outcomes Tables: Individual Neuropsychological Tests/Cognitive Domains - AVR

Appendix J. Table 3 Cognitive Outcomes Tables: Individual Neuropsychological Tests/Cognitive Domains – CAS and CEA