# Cognitive Outcomes Tables: Incident Cognitive Impairment Defined by Composite of Neuropsychological Tests

Appendix I. Table 1 Cognitive Outcomes Tables: Incident Cognitive Impairment Defined by Composite of Neuropsychological Tests - CABG

Study/ Design | Neuropsychological composite cognitive impairment (CI) n/N (%)
Study/ Design | Pre-Procedure cognitive status | | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up
Study/ Design | Intervention | Control | Intervention | Control | Intervention | Control
Lamy, 2013^1^ Off-pump CABG (n=2375) vs. On-pump CABG (n=2377)/ RCT | NR | NR | NR | NR | NR | NR
Jensen, 2006;^24^ 2008^2^ Off-pump CABG (n=61) vs. On-pump CABG (n=59)/RCT | All subjects had MMSE >24 (score ≥25 points out of 30 indicates a normal cognition) | All subjects had MMSE >24 | [underlined: 3 months] Definition 1 4/54 (7.4) RR 0.76 [0.21 to 2.66]; P=0.66 Definition 2 11/54 (20.4) RR 0.87 [0.42 to 1.78]; P=0.70 Definition 3 14/54 (26.0) RR 1.20 [0.60 to 2.40]; P=0.60 [underlined: 12 months] Definition 1 9/47 (19.1) RR 2.06 [0.68 to 6.20]; P=0.20 Definition 2 6/47 (12.8) RR 1.10 [0.36 to 3.34]; P=0.87 Definition 3 14/47 (29.8) RR 1.07 [0.56 to 2.05]; P=0.84 | [underlined: 3 months] Definition 1 5/51 (9.8) Definition 2 12/51 (23.5) Definition 3 11/51 (21.6) [underlined: 12 months] Definition 1 4/43 (9.3) Definition 2 5/43 (11.6) Definition 3 12/43 (27.9) | NR | NR
Vedin, 2006^3^ Off-pump CABG (n=33) vs. On-pump CABG (n=37) / RCT | NR | NR | [underlined: 6 months] 5/33 (15) RR 0.80 [0.28 to 2.28]; P=0.68 | [underlined: 6 months] 7/37 (19) | NR | NR
Lund, 2005^4^ Off-pump CABG (n=60) vs. On-pump CABG (n=60) / RCT | NR | NR | [underlined: 3 months] 11/54 (20.4) RR 0.88 [0.43 to 1.82]; P=0.74 [underlined: 12 months] 13/54 (24.1) 1.04 [0.53 to 2.07]; P=0.90 | [underlined: 3 months] 12/52 (23.1) [underlined: 12 months] 12/52 (23.1) | NR | NR
Lee, 2003^5^ Off-pump CABG (n=30) vs. On-pump (n=30) / RCT | NR | NR | [underlined: 12 months] 5/27 (18.5) RR 1.25 [0.38 to 4.16]; P=0.72 | [underlined: 12 months] 4/27 (14.8) | NR | NR
Selnes, 2009;^20^ McKhann, 2005^28^ Off-pump CABG (n=75) vs. On-pump CABG (n=152) / Prosp. | Mean MMSE = 27.7; 4.2% had a MMSE score <24 | Mean MMSE = 27.6; 4.6% had a MMSE score <24 | NR | NR | NR | NR
Selnes, 2009;^20^ McKhann, 2005^28^ Off-pump CABG (n=75) vs. Non-surgical control (n=99)/ Prosp. | Mean MMSE = 27.7; 4.2% had a MMSE score <24 | Mean MMSE = 27.9; 6.1% had a MMSE score <24 | NR | NR | NR | NR
Selnes, 2009^20^/ McKhann, 2005^28^ On-pump CABG (n=152) vs. Non-surgical control (n=99)/ Prosp. | Mean MMSE = 27.6; 4.6% had a MMSE score <24 | Mean MMSE = 27.9; 6.1% had a MMSE score <24 | NR | NR | NR | NR
Boodhwani, 2007^6^ Normothermic (n=134) versus Hypothermic (n=133)/ RCT | NR | NR | [underlined: 3 months] n/N, NR (4) | [underlined: 3 months] n/N, NR (8) | NR | NR
Nathan, 2001;^7^ 2007^8^ Normothermic (n=112) versus Hypothermic (n=111)/ RCT | NR | NR | NR | NR | [underlined: 5 years] 27/65 (42) RR 0.95 [0.64 to 1.41]; P=0.78 | [underlined: 5 years] 29/66 (44)
Djaiani, 2012^9^ Cell-saver (n=84) vs. Control (n=86)/ RCT | NR | NR | NR | NR | [underlined: 1 year] 16/84 (19.0) RR 1.09 [0.58 to 2.06]; P=0.79 | [underlined: 1 year] 15/86 (17.4)
Anastasiadis, 2011^10^ MECC (n=32) vs. CECC (n=32) / RCT | NR | NR | [underlined: 3 months] 6/29 (21) RR 0.34 [0.16 to 0.73]; P=0.005 | [underlined: 3 months] 19/31 (61) | NR | NR
Flesch, 2009^11^ CABG with candesartan (n=53) vs. CABG with placebo (n=53)/ RCT | NR | NR | NR | NR | NR | NR
Silbert, 2006^12^ CABG with low dose fentanyl (n=180) vs. CABG with high dose fentanyl (n=170) / RCT | NR | NR | [underlined: 12 months]^†^ 20% rule: 42/159 (26) RR 1.10 [0.74 to 1.62]; P=0.65 1 SD rule: 24/159 (15) RR 1.18 [0.67 to 2.09]; P=0.56 | [underlined: 12 months]^†^ 20% rule: 34/141 (24) 1 SD rule: 18/141 (13) | NR | NR
Alex, 2005^13^ Atmospheric air (n=31) vs. Hyperbaric oxygen (n=33)/ RCT | NR | NR | [underlined: 4 months] 9/33 (27.3) RR 0.53 [0.27 to 1.02]; P=0.06 | [underlined: 4 months] 16/31 (51.6) | NR | NR
Kadoi, 2003^27^ CABG with propofol (n=90) vs. CABG with fentanyl (n=90)/ RCT | NR | NR | [underlined: 6 months:] 5/77 (6) RR 0.97 [0.29 to 3.23]; P=0.97 | [underlined: 6 months:] 5/75 (7) | NR | NR
Gold, 1995^15^ Low MAP (n=124) vs. High MAP (n=124)/ RCT | NR | NR | [underlined: 6 months] n/N, NR (11) | [underlined: 6 months] n/N, NR (12) | NR | NR
Andrew, 2001^21^ Extracardiac (n=59) vs. Intra-cardiac (n=50) | NR | NR | NR | NR | NR | NR

CI = cognitive impairment; MMSE = Mini–mental state examination; NR = not reported; RR = risk ratio [95% confidence intervals]

* Decision to participate in neurocognitive testing was optional but decided prior to randomization to avoid biases.

[underlined: Neuropsychological composite cognitive impairment outcomes definitions:]

Jensen 2006: There were 3 definitions

1. occurrence of at least 2 of 7 possible deficits in A) Visual Verbal Learning; B) Concept Shifting Task; C) Stroop Color Word Interference; and D) Letter-Digit Coding. The 7 possible deficits were 2 possible deficits in A, B, and C and 1 possible deficit in D. For the 2 error scores, a deficit was defined as ≥4 additional errors postoperatively compared with Pre-Procedurely out of 16 possible in B and ≥5 additional errors postoperatively compared with Pre-Procedurely out of 40 possible in C.
2. 20% decline in cognitive scores compared with baseline.
3. International Study of Post-Operative Cognitive Dysfunction definition, in which changes in the performance of 7 parameters from the result of the 4 tests were calculated. For each individual test outcome, the average learning effect was subtracted from these changes, and a z score was obtained after division by the SD from an age-matched healthy control group. When 2 of 7 z scores in individual tests or the combined z score were 1.96 or more, patients were defined as having cognitive dysfunction.

Vedin 2006: 20% decline in 20% (or two) of the cognitive tests (Digit Span, Block Span, Trail-Making Test A—D, Digit-symbol, COWAT-FAS, Claeson-Dahl Verbal Learning Test & Claeson-Dahl Verbal Retention Test) according to ‘Statement of Consensus on Assessment of Neurobehavioral Outcomes after Cardiac Surgery.’

Lund 2005: >20% decrease on at least two tests (Grooved Pegboard Test, Digit Symbol [WAIS-R], Trail Making Test, Digit Span [WAIS-R], Stroop Color-Word Interference Test, Rey Auditory Verbal Learning Test, L and R, Similarities [WAIS-R], Controlled Oral Association Test [COWAT]), and Block Design [WAIS-R] at the 3-or the 12-month control compared with the Pre-Procedure assessment were defined as cognitively impaired.

Lee 2003: 20% decline in 20% (or two) of the cognitive tests (Vocabulary subtest Wechsler Adult Intelligence Scale (WAIS III), Rey Auditory Verbal Learning Test, Benton Visual Retention Test, Trail Making Test, Parts A and B, Grooved Pegboard Test, Finger Tapping Test, Digit Symbol subtest of the WAIS III), using the recommended core neuropsychological battery according to the 1994 Conference on CNS Dysfunction.

Boodhwani, 2007 Deficit was prospectively defined as a 1 standard deviation decrease in individual scores from baseline in 1 or more domains. RAVLT, Rey Auditory Verbal Learning Test; WMS, Wechsler Memory Scale; SDMT, Symbol Digit Modalities Test.

Nathan 2001, 2007 A patient was classified as having a cognitive deficit if a decrease of ≥ 0.50 SD was realized in 1 or more domains.

Djaiani, 2012 Patients with a negative score of\1 were considered to have POCD

Anastasiadis 2011: Cognitive decline defined as a decline of 1 SD or more (based on normative data relative to Pre-Procedure performance) in one ormore of the neurocognitive tests.

Silbert 2006: Two or more abnormal test results based on 1) “20% rule”: decrease of 20% for each individual from baseline (per Rasmussen et al NNewman et al) or on 2) “1 SD rule”: a decrease of an individual’s score of at least 1 standard deviation of the baseline mean for all patients for the relevant test (per Keizer et al and Lewis et al)

Alex, 2005 A postoperative deterioration of greater than 1 SD from the Pre-Procedure score in 2 or more tests (28% of the tests) was considered significant neuropsychometric impairment. (Tests included: the adult memory and information-processing table A, digit span forward, and digit span backward, in addition to the 4 recommended core tests [trail making A, trail making B, grooved peg board, and the Rey auditory verbal learning test.])

Kadoi 2003: “Significant impairment” was defined as a decline from Pre-Procedure testing of more than one standard deviation on more than 20% of test measures (at least two of six tests: Mini-Mental Test, Rey Auditory Verbal Learning Test, (3) Trail-Making Test (part A), Trail-Making Test (part B), digit span forward, or grooved pegboard).

Gold, 1995 Deterioration on three or more cognitive tests was defined as a cognitive complication.

† Silbert also reported composite outcomes at 3 months

Appendix I. Table 2 Cognitive Outcomes Tables: Incident Cognitive Impairment Defined by Composite of Neuropsychological Tests - AVR

Study | Neuropsychological composite cognitive impairment (CI) (n/N) %
Study | Pre-Procedure Cognitive Status | | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up
Study | Intervention | Control | Intervention | Control | Intervention | Control
Knipp, 2013^23^ AVR (n=37) vs. TA-TAVI (n=27) | NR | NR | [underlined: 3 months] 2/34 (6) P=0.04 | [underlined: 3 months] 5/18 (28) | NR | NR
Fakin, 2012^18^ Hypothermic AVR (n=30) vs. Normothermic (n=30) | NR | NR | NR | NR | NR | NR
Andrew, 2001^21^ Intracardiac (n=50) vs. Extracardiac (n=59) | NR | NR | NR | NR | NR | NR

CI = cognitive impairment; NR = not reported; TA-TAVI = transapical transcatheter aortic valve implantation Neuropsychological composite cognitive impairment outcomes definitions:

1. Knipp 2013 – a cognitive composite test score (defined as difference between the number of tests with improvement and decline) of ≤−2 in TA-TAVI patients and ≤−3 in AVR patients denoted a clinically significant cognitive decline in the individual patient.
2. Fakin, 2011 – reported correlation between neurocognitive brain function measured by P300 auditory evoked potentials between pre-procedure and 4 months (repeated measures analysis of variance)

Appendix I. Table 3 Cognitive Outcomes Tables: Incident Cognitive Impairment Defined by Composite of Neuropsychological Tests – CAS and CEA

Study | Neuropsychological composite cognitive impairment (CI) (n/N) %
Study | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up
Study | Intervention | Control | Intervention | Control
Altinbas, 2011^16^ CAS (n=71) vs CEA (n=69) RCT | NR | NR | NR | NR
Baracchini, 2012^22^ CEA (n=145) vs. Laparoscopic cholecystectomy Control (n=68) Prospective observational cohort study | NR | NR | NR | NR
Crawley, 2000^17^ CEA (n=26) vs carotid PTA (n=20) RCT | [underlined: 6 months] 4/22 (18) RR 0.47 [0.16 to 1.35]; P=0.16 | [underlined: 6 months] 7/18 (38) | NR | NR

CI = cognitive impairment; NR = not reported; PTA: percutaneous transluminal angiography; RR = risk ratio [95% confidence intervals]

Neuropsychological composite cognitive impairment outcomes definitions:

Crawley 2000: A drop in the postoperative score by ≥ 1 SD from the pre-procedure score.