# Cognitive Outcomes Tables: Clinically Diagnosed Cognitive Impairment

Appendix H. Table 1 Cognitive Outcomes Tables: Clinically Diagnosed Cognitive Impairment - CABG

Study | Confirmed symptomatic CI* associated with functional impairment (n/N) % | | | | Confirmed symptomatic CI* [underlined: not] associated with functional impairment, clinically diagnosed (n/N) %
Study | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up | | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up
Study | Intervention | Control | Intervention | Control | Intervention | Control | Intervention | Control
Lamy, 2013^1^ Off-pump CABG (n=2375) vs. On-pump CABG (n=2377)/ | NR | NR | NR | NR | NR | NR | NR | NR
Jensen, 2006;^24^ 2008^2^ Off-pump CABG (n=61) vs. On-pump CABG (n=59) | NR | NR | NR | NR | NR | NR | NR | NR
Vedin, 2006^3^ Off-pump CABG (n=33) vs. On-pump CABG (n=37) | NR | NR | NR | NR | NR | NR | NR | NR
Lund, 2005^4^ Off-pump CABG (n=60) vs. On-pump CABG (n=60) | NR | NR | NR | NR | NR | NR | NR | NR
Lee, 2003^5^ Off-pump CABG (n=30) vs. On-pump (n=30) | NR | NR | NR | NR | NR | NR | NR | NR
Selnes, 2009^20^ Off-pump CABG (n=75) vs. On-pump CABG (n=152) | NR | NR | NR | NR | NR | NR | NR | NR
Selnes, 2009^20^ Off-pump CABG (n=75) vs. Non-surgical control (n=99)/ | NR | NR | NR | NR | NR | NR | NR | NR
Selnes, 2009^20^ On-pump CABG (n=152) vs. Non-surgical control (n=99) | NR | NR | NR | NR | NR | NR | NR | NR
Boodhwani, 2007^6^ Normothermic (n=134) vs. Hypothermic [n=133]) | NR | NR | NR | NR | NR | NR | NR | NR
Nathan, 2001;^7^ 2007^8^ Normothermic (n=112) vs. Hypothermic (n=111) | NR | NR | NR | NR | NR | NR | NR | NR
Djaiani, 2012^9^ Cell-saver (n=84) vs. Control (n=86) | NR | NR | NR | NR | NR | NR | NR | NR
Anastasiadis 2011;^10^ MECC (n=32) vs. CECC (n=32) | NR | NR | NR | NR | NR | NR | NR | NR
Flesch, 2009^11^ CABG with candesartan (n=53) vs. CABG with placebo (n=53) | NR | NR | NR | NR | NR | NR | NR | NR
Silbert, 2006^12^ CABG with low dose fentanyl (n=180) vs. CABG with high dose fentanyl (n=170) | NR | NR | NR | NR | NR | NR | NR | NR
Alex, 2005^13^ Atmospheric air (n=31) vs. Hyperbaric oxygen (n=33) | NR | NR | NR | NR | NR | NR | NR | NR
Kadoi, 2003^27^ CABG with propofol (n=90) vs CABG with fentanyl (n=90) | NR | NR | NR | NR | NR | NR | NR | NR
Gold, 1995^15^ Low MAP (n=124) vs. High MAP (n=124) | NR | NR | NR | NR | NR | NR | NR | NR
Andrew, 2001^21^ Extracardiac (n=59) vs. Intracardiac (n=50) | NR | NR | NR | NR | NR | NR | NR | NR

CI = cognitive impairment; NR = not reported; MECC = minimal extracorporeal circulation; CECC = conventional extracorporeal circulation

Appendix H. Table 2 Cognitive Outcomes Tables: Clinically Diagnosed Cognitive Impairment - AVR

Study | Confirmed symptomatic CI associated with functional impairment (n/N) % | | | | Confirmed symptomatic CI [underlined: not] associated with functional impairment, clinically diagnosed (n/N) %
Study | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up | | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up
Study | Intervention | Control | Intervention | Control | Intervention | Control | Intervention | Control
Knipp, 2013^23^ AVR (n=37) vs. TA-TAVI (n=27)
Fakin, 2011^18^ Hyppthermic AVR (n=30) vs. Normothermic (n=30) | NR | NR | NR | NR | NR | NR | NR | NR
Andrew, 2001^21^ Intracardiac (n=50) vs. Extracardiac (n=59) | NR | NR | NR | NR | NR | NR | NR | NR

CI = cognitive impairment; NR = not reported; TA-TAVI = transapical transcatheter aortic valve implantation

Appendix H. Table 3 Cognitive Outcomes Tables: Clinically Diagnosed Cognitive Impairment – CAS and CEA

Study | Confirmed symptomatic CI associated with functional impairment (n/N) % | | | | Confirmed symptomatic CI [underlined: not] associated with functional impairment, clinically diagnosed (n/N) %
Study | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up | | Intermediate-term (3–12 months) follow-up | | Long-term (>12 months) follow-up
Study | Intervention | Control | Intervention | Control | Intervention | Control | Intervention | Control
Altinbas, 2011^16^ CAS (n=71) vs. CEA (n=69) | NR | NR | NR | NR | NR | NR | NR | NR
Baracchini, 2012^22^ CEA (n=145) vs. Laparoscopic cholecystectomy Control (n=68) | NR | NR | NR | NR | NR | NR | NR | NR
Crawley, 2000^17^ Carotid PTA (n=20) vs. CEA (n=26) | NR | NR | NR | NR | NR | NR | NR | NR

CI = cognitive impairment; NIHSS= National Institutes of Health Stroke Scale; NR = not reported; PTA=percutaneous transluminal angioplasty; RCT=raandomized controlled trial