# Evidence Tables

Appendix G. Table 1 Evidence table: Coronary Artery Bypass Grafting Studies

Appendix G. Table 2 Evidence table: Aortic Valve Replacement Studies

Appendix G. Table 3 Evidence table: Carotid Artery Stenting and Endarterectomy