# Risk of Bias

Appendix F. Table 1 Assessment of individual study quality for Randomized controlled trials/Controlled clinical trials based on risk of bias (low-risk, high-risk, or unclear)

Study year | Random sequence generation | Allocation concealment | Masking | Attrition bias accounted for | Intention-to- treat analysis | Selective outcomes reporting | Overall risk of bias^*^
CABG Studies
Lamy, 2013^1^ | Low-risk | Low-risk | Low-risk | Low-risk | High-risk | Low-risk | Moderate
Jensen, 2008^2^ | Low-risk | Low-risk | Low-risk | Low-risk | High-risk^**^ | Low-risk | Moderate
Vedin, 2006^3^ | Unclear | Unclear | Unclear | Low-risk | High-risk^**^ | Low-risk | Unclear
Lund, 2005^4^ | Unclear | Unclear | Low-risk | Low-risk | High-risk^**^ | Low-risk | Moderate
Lee, 2003^5^ | Unclear | Unclear | Low-risk | Low-risk | High-risk^**^ | Low-risk | Unclear
Boodhwani, 2007^6^ | Low-risk | Low-risk | Low-risk | Unclear | High-risk^**^ | Low-risk | Moderate
Nathan, 2001^7^/2007^8^ | Low-risk | Low-risk | Low-risk | Low-risk | High-risk^**^ | Low-risk | Moderate
Djaiani, 2012^9^ | Low-risk | Unclear | Low-risk | Unclear | High-risk^*^ | Low-risk | Unclear
Anastasiadis, 2011^10^ | Low-risk | Low-risk | Low-risk | Low-risk | High-risk^**^ | Low-risk | Moderate
Flesch, 2009^11^ | Unclear | Unclear | Unclear | Low-risk | High-risk^**^ | Low-risk | Unclear
Silbert, 2006^12^ | Low-risk | Unclear | Low-risk | Low-risk | High-risk^**^ | Low-risk | Moderate
Alex, 2005^13^ | Low-risk | Low-risk | Low-risk | Unclear | Unclear | Low-risk | Unclear
Kadoi, 2003^14^ | Unclear | Unclear | Low-risk | Unclear | High-risk^**^ | Low-risk | Unclear
Gold, 1995^15^ | Low-risk | Unclear | Low-risk | Low-risk | High-risk^**^ | Low-risk | Moderate
CAS/CEA Studies
Altinbas, 2011^16^ | Low-risk | Low-risk | Unclear | Low-risk | High-risk^**^ | Low-risk | Moderate
Crawley, 2000^17^ | Low-risk | Low-risk | Low-risk | Low-risk | High-risk^**^ | Low-risk | Moderate
AVR Studies
Fakin, 2012^18^ | Low-risk | Unclear | Unclear | Unclear | Unclear | Low-risk | Unclear

CABG = Coronary artery bypass grafting; CAS = carotid artery stenting; CEA = Carotid endarectomy; AVR=aortic valve replacement

* Low risk of bias when individual interventional studies meet all quality criteria, a moderate risk of bias if at least one of the quality criteria is not met, high risk of bias if multiple quality criteria are not met, and unclear risk of bias if sequence generation, allocation concealment, and blinding methods were not reported.

** Completers only

Appendix F. Table 2 Assessment of individual study quality for observational studies based on risk of bias (low-risk, high-risk, or unclear)

Study year | Baseline groups similar in prognostic indicators | Attrition bias accounted for | Masking | Reporting bias from selective outcomes reporting | Overall risk of bias^*^
McKhann, 2009^19^/ Selnes, 2009^20^ | High-risk | High-risk | Unclear | Low-risk | High
Andrew, 2001^21^ | Low-risk | Low-risk | Unclear | Low-risk | Moderate
Baracchini, 2012^22^ | High-risk | High-risk | Low-risk | Low-risk | High
Knipp, 2013^23^ | High-risk | High-risk | Unclear | Low-risk | High

* Low risk of bias when individual prospective observational cohort studies meet all quality criteria, a moderate risk of bias if at least one of the quality criteria is not met, and a high risk of bias if multiple quality criteria are not met