# Patient Characteristics

Appendix E. Table 1 Summary of study baseline characteristics for all studies

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 7802 (46 to 4752) | 21
Total number of patients evaluated from RCTs, % | 91 (n=7076; 46 to 4752) | 17
Total number of patients evaluated from observational studies, % | 9 (n=726; 64 to 326) | 4
Study withdrawals (RCTs), % of patients | 17 (5 to 41) | 14
Age of subjects, years | 68 (65 to 76) | 21
Gender, male, % of patients | 80 (41 to 93) | 20
Race/ethnicity, white, % of patients | 92 (92 to 93) | 2
Education, high school, vocational school, or less, % of patients | 60 (39 to 87) | 4^*^
Education, post-secondary, % of patients | 40 (13 to 61) | 4^*^
Education, years | 11 (7 to 14) | 6
History of diabetes, % of patients | 39 (0^**^ to 47) | 20
History of myocardial infarction, % of patients | 36 (9 to 73) | 13
History of stroke, % of patients | 6 (0^**^ to 8) | 10^†^
History of depression, % of patients | 0^**^ | 2
Studies conducted in United States/Canada, % of patients | 17 (n=1350) | 6
Studies conducted in Europe, % of patients | 14 (n=1085) | 11
Studies conducted in Australasia, % of patients | 8 (n=615) | 3
Multinational (North America and Europe), % of patients | 61 (n=4752) | 1
CABG studies, % of patients | 93 (n=7265) | 16
CEA/CAS studies, % of patients | 5 (n=413) | 3
AVR studies, % of patients | 3 (n= 233) | 3^††^

NR = not reported; RCT = randomized controlled trial; CAGB = Coronary artery bypass grafting; CEA = Carotid endarterectomy; CAS = Carotid artery stenting; AVR = Aortic valve replacement.

* In addition, one trial (Gold 1995) also reported that ≥90% of enrollees had at least a high school education.

** Indicates this was an exclusion criterion for study entry

† In addition, one CEA trial (Altinbas 2011) reported 46% of enrollees had a recent ischemic stroke based in imaging.

†† Percent and number of studies do not add up to 100% and 21, respectively. One study (Andrew 2001) has a CAGB arm as control.

Appendix E. Table 2 Summary of study baseline characteristics for CABG studies

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 7265 (60 to 4752) | 16
Total number of patients evaluated from RCTs, % | 94 (n=6830; 60 to 4752) | 14
Total number of patients evaluated from observational studies, % | 6 (n=435; 109 to 326) | 2
Study withdrawals (RCTs), % of patients | 18 (5 to 41) | 12
Age of subjects, years | 68 (65 to 76) | 16
Gender, male, % of patients | 81 (60 to 93) | 16
Race/ethnicity, white, % of patients | 92 (92 to 93) | 2
Education, high school, vocational school, or less, % of patients | 60 (39 to 87) | 4^*^
Education, post-high school, % of patients | 40 (13 to 61) | 4^*^
Education, years | 12 (8 to 14) | 5
History of diabetes, % of patients | 40 (0^*^ to 47) | 15
History of myocardial infarction, % of patients | 36 (9 to 73) | 12
History of stroke, % of patients | 6 (0^**^ to 8) | 10
History of depression, % of patients | 0^**^ | 2
Studies conducted in United States/Canada, % of patients | 19 (n=1350) | 6
Studies conducted in Europe, % of patients | 8 (n=548) | 6
Studies conducted in Australasia, % of patients | 8 (n=615) | 3
Multinational (North America and Europe), % of patients | 65 (n=4752) | 1

NR = not reported; RCT = randomized controlled trial. CAGB = Coronary artery bypass grafting.

* In addition, one trial (Gold 1995) also reported that ≥90% of enrollees had at least a high school education.

** Indicates this was an exclusion criterion for study entry

Appendix E. Table 3 Summary of study baseline characteristics for AVR studies

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 233 (60 to 109) | 3
Total number of patients evaluated from RCTs | 60 | 1
Total number of patients evaluated from observational studies | 173 (64 to 109) | 2
Study withdrawals (RCTs), % of patients | NR | -
Age of subjects, years | 68 (66 to 74) | 3
Gender, male, % of patients | 66 (41 to 80) | 2
Race/ethnicity, white, % of patients | NR | -
Education, high school, vocational school, or less, % of patients | NR | -
Education, post-high school, % of patients | NR | -
Education, years | 10.2 | 1
History of diabetes, % of patients | 22 (17 to 33) | 3
History of myocardial infarction, % of patients | NR | -
History of stroke, % of patients | 0^*^ | 1
History of depression, % of patients | NR | -
Studies conducted in United States/Canada, % of patients | 0
Studies conducted in Europe, % of patients | 53 (n=124) | 2
Studies conducted in Australasia, % of patients | 47 (n=109) | 1

NR = not reported; RCT = randomized controlled trial; AVR = Aortic valve replacement.

* Indicates this was an exclusion criterion for study entry

Appendix E. Table 4 Summary of study baseline characteristics for CAS / CEA studies

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 413 (46 to 227) | 3
Total number of patients evaluated from RCTs | 186 (46 to 140) | 2
Total number of patients evaluated from observational studies | 227 | 1
Study withdrawals (RCTs), % of patients | 15 (13 to 15) | 2
Age of subjects, years | 72 (68 to 74) | 3
Gender, male, % of patients | 72 (71 to 74) | 3
Race/ethnicity, white, % of patients | NR | -
Education, high school, vocational school, or less, % of patients | NR | -
Education, post-high school, % of patients | NR | -
Education, years | 7.2 | 1^*^
History of diabetes, % of patients | 28 (7 to 36) | 3
History of myocardial infarction, % of patients | 16 | 1
History of stroke, % of patients | 46^**^ | 1
History of depression, % of patients | NR | -
Studies conducted in United States/Canada, % of patients | 0
Studies conducted in Europe, % of patients | 100 (n=413) | 3
Studies conducted in Australasia, % of patients | 0

NR = not reported; RCT = randomized controlled trial; CEA = Carotid endarterectomy; CAS = Carotid artery stenting; AVR = Aortic valve replacement.

* Another study (Altinbas) also reported education with undefined units.

** Recent ischemic stroke based in imaging.