# Neuropsychological Test Descriptions

Most Commonly Reported Testing Procedures by Cognitive Domain

| Count of Studies by Domain or Test
Total Studies Reviewed, N=21 | N | %
Attention | 18 | 85.7
Trail Making Test A * | 16 | 76.2
Digit Span Forward | 11 | 52.4
Language | 12 | 57.1
Verbal Fluency Tests | 10 | 47.6
Other Language Tests (includes BNT) | 6 | 28.6
Boston Naming Test | 4 | 19.1
Memory | 18 | 85.7
Rey Auditory Verbal Learning Test * | 9 | 42.9
Verbal List Learning Tests (includes RVLT) | 15 | 71.4
Non-Verbal Memory Tests | 5 | 23.8
Visuospatial | 7 | 33.3
Spatial Span / Corsi Blocks | 3 | 14.3
Other Visuospatial tests | 4 | 19.1
Executive | 20 | 95.2
Trail Making Test B * | 18 | 85.7
Digit Symbol / Symbol Digit Modalities | 11 | 52.4
Digit Span Backwards | 10 | 47.6
Psychomotor | 14 | 66.7
Grooved Pegboard * | 10 | 47.6
Finger Tapping | 4 | 19.1
Complex Reaction Time Tests | 4 | 19.1
Intellectual Ability | 8 | 38.1
FSIQ or IQ Estimate | 5 | 23.8
National Adult Reading Tests | 3 | 14.3
Screening Tests | 8 | 38.1
Mini Mental State Exam | 6 | 28.6
Montreal Cognitive Assessment | 3 | 14.3

* Tests recommended by the 1995 Consensus Statement

[underlined: Note.] Although many testing procedures evaluate multiple cognitive abilities, for simplicity in reporting, all have been assigned to one primary domain. The reader is referred to Appendix J for detailed reporting of test results by cognitive domain in which tests are replicated across all relevant cognitive domains.

## Brief Descriptions of the Most Commonly Used Measures/Testing Procedures

*The tests recommended by the 2005 consensus statement publication include the following:

### Trail Making Test*

The Trail Making Test (TMT) is in the public domain and substantial normative data exists for clinical interpretation. In Trail A, subjects are asked to draw lines connecting circled numbers on a page in sequence as quickly as they can. In Trail B, one alternates between numbers and letters. In each condition, the primary score is the time to complete the task, and it is common to also track errors during performance. Trail A measures visual attention and processing speed. Trail B taps executive abilities including set shifting and mental flexibility. The TMT was included in the 2005 consensus statement recommendation, and was the most commonly reported test in the studies reviewed (76% Trial A, 86% Trail B). Appropriately, most studies reported separate scores (time for completion) for Trail A and B or a difference score between the two conditions.

### Digit Span

The Digit Span test is a subtest of both the Wechsler Adult Intelligence Scale (WAIS) and the Wechsler Memory Scales (WMS). Subjects are read a sequence of numbers and asked to repeat the same sequence back to the examiner in order (forward span) or in reverse order (backward span). Forward span captures attention efficiency and capacity. Backward span is an executive task particularly dependent on working memory. The Digit Span subtest can be scored as one summary value (this is the score which is age-normed and contributes to summary scores in the Wechsler tests), or separately for forwards and backwards performance. Forwards and backwards performance can be reported either as subscores (the number of correct items of each type) or as span scores (the maximum number of digits correctly produced forwards or backwards by the subjects). Approximately half (forwards 52%, backwards 48%) of the studies reviewed reported Digit Span scores. There was relatively common use of the summary score, as opposed to reporting forward and backward span separately. Although this is how the subtest is totaled and age-normed for use in the Wechsler tests, it provides less information than evaluating separate forwards and backwards scores (age-based means and standard deviations are provided for individual forward and backward spans). When separate scores were provided for forwards and backwards, it was rarely stated whether these were Wechsler subscores scores (representing multiple items at each span level) or maximum span scores. Clear reporting not only of separate forwards and backwards scores, but also of the specific metric (subscore or maximal span) is essential to characterizing subject performance (demographic-based norming) and evaluating whether data can pooled across multiple studies.

### Digit Symbol / Symbol Digit Modalities

Digit Symbol (from the Wechsler Adult Intelligence Scale) and Symbol Digit Modalities are similar symbol substitution tasks in which subjects are presented with rows of numbers (or symbols for Symbol Digit Modalities) and asked to substitute the corresponding symbol (or number) from a key provided above. The task is timed and subjects are asked to complete the task as quickly as possible. The primary score consists of the number of items completed in a specified amount of time (varies by version) and is influenced by psychomotor ability, sustained attention, processing speed and to a lesser degree working memory. Secondary metrics can be calculated to evaluate incidental learning during the testing procedure, and a copy/motor version of the task is available to evaluate the relative contribution of motor versus cognitive aspects of task performance. Approximately half of the studies reviewed report using either the Digit Symbol or Symbol Digit Modalities test (52%). Because there are multiple versions of this general test format, it is important to specify the specific version of the test used in order to characterizing subject performance (demographic-based norming) and evaluate whether data can pooled across multiple studies. In many cases, not enough information was reported in the publication to determine the exact version of the test administered (e.g. WAIS-R vs. WAIS-III).

### Verbal Fluency Tests

Verbal fluency tests are measures of spontaneous verbal production. The two most common types are 1) phonemic fluency (letter fluency), in which one is asked to produce words beginning with a specified letter or sound (often “F”, “A” and “S” or “C”, “F” and “L”), and 2) semantic fluency (category fluency), in which one is asked to produced words that belong to a specified category (often “animals” or “fruits and vegetables”). Subjects are asked to provide as many examples of the rule (letter or category) as they can in one minute. The primary score is the number responses produced minus errors (e.g., repeats or invalid responses such as proper nouns or out of letter/category). Phonemic fluency tests are most often scored summing the total words produced over three letters (one minute for each). Verbal fluency tests evaluate expressive language ability, executive function, and are influenced by processing speed and potentially memory (semantic). Verbal fluency tests were the most common language tests reported (48%), with phonemic (letter) fluency reported more frequently than semantic fluency. This may in part be due to phonemic fluency being the more difficult of the two tasks and having a somewhat stronger association with executive function. The studies reviewed varied in the specificity with which they reported verbal fluency testing procedures and it was often unclear whether phonemic or semantic testing was administered, and what specific letters or categories were used. Without this information, mean subject scores cannot be compared to relevant normative data to evaluate performance, and data across studies cannot be aggregated for analysis.

### Boston Naming Test

The Boston Naming test is a test of confrontation naming in which subjects are asked to name objects presented visually as two dimensional line drawings in a booklet. If the subject fails to produce the correct name within 20 seconds, phonemic and/or semantic cues can be provided depending on whether the subject is able to correctly perceive the image. The primary score is the number of correctly identified objects within the initial 20 second presentation. Although the test evaluates language, not surprisingly, it is influenced by visuospatial deficits. The Boston Naming Test was the second most popular language test reported, used by 19% of studies. There are different forms of the test, primarily varying by the number of items presented. When reported, mean scores often appeared out of range for the most common 60-item version of the test, but no further specification was provided about the version administered. Again, this information is essential for evaluating performance and aggregating data across studies.

### Tests of List Learning

Many studies reported verbal memory tests of list learning, in which subjects are read a list of words and asked to recall the list both immediately in learning trials and later for delayed recall trials, and often as a recognition task with the list embedded in distractor words. These tests evaluate verbal memory, both short and long term storage, as well as often the ability to benefit from learning strategies and cueing on recall (encoding versus storage). Seventy-one percent of the studies reviewed reported some type of verbal list learning task. The most commonly reported test of this type (43%) was the Rey Auditory Verbal Learning Test (RAVLT) which had been recommended in Murkin et al.’s 1995 consensus statement publication. There are often many different scores produced by these tests. Although most studies reported enough information to determine both the specific test (e.g. RAVLT, CVLT, CERAD) and score (e.g. sum of trials, free delayed recall, recognition hits), some failed to report this information. Additionally, there were cases in which a total summary score was calculated that is not commonly reported. Although this practice does not necessarily detract from the individual study findings, it does make it more difficult to compare findings across studies and evaluate subject performance relevant to published normative data.

### Grooved Pegboard

Many of the studies reviewed employed pegboard tests to evaluate their subjects’ psychomotor ability. The most commonly reported (48%) was the Grooved Pegboard which had been recommended in Murkin et al.’s 1995 Consensus Statement publication. Grooved Pegboard tests manipulative dexterity, evaluating the coordination of fine motor movements on both sides of the body. Subjects are asked to place grooved pegs (like simple keys) into holes with matching slots such that the pegs must be rotated before they can be inserted. Multiple trials are administered separately for each the dominant and non-dominant hand, and the primary score is the time to complete 25 pegs. It is common to also record the number of times a subject drops a peg. The test requires visual and motor coordination, and is good for evaluating lateralized deficits such as those that may accompany stroke. Although Grooved Pegboard was very commonly reported, and most studies correctly presented dominant and non-dominant (or right vs. left) scores separately, many of the scores reported were substantially out of range of the published normative data for the study’s reported subject demographics. Complete reporting of the specific testing procedures and scoring will help to make these results both more clinically meaningful and comparable across studies.