# Search Strategy

Database: Ovid MEDLINE(R) <1946 to January Week 3 2013>

Search Strategy:

1 | comprehension/ (6633)
2 | cognition disorders/ (44130)
3 | auditory perceptual disorders/ (909)
4 | memory/ (49313)
5 | memory, episodic/ (472)
6 | memory, long-term/ (371)
7 | memory, short-term/ (13113)
8 | mental recall/ (25327)
9 | retention, psychology/ (7518)
10 | memory disorders/ (13433)
11 | exp Neuropsychological Tests/ (61191)
12 | exp Executive Function/ (3065)
13 | exp Psychometrics/ (49676)
14 | exp Psychomotor Disorders/ (10067)
15 | exp Psychomotor Performance/ (78939)
16 | Dementia/ or Alzheimer disease/ or aphasia, primary progressive/ or dementia, vascular/ or frontotemporal lobar degeneration/ or lewy body disease/ (90697)
17 | pick disease of the brain/ (351)
18 | mild cognitive impairment/ (762)
19 | central nervous system dysfunction.mp. (498)
20 | neuropsychological impairment.mp. (860)
21 | (Cognitive decline or cognitive dysfunction or cognitive tests or cognitive assessment or cognitive function or cognitive evaluation or cognitive performance or cognitive change or cognitive problem or cognitive outcome or cognitive sequelae).mp. (33149)
22 | (Neuropsychologic* decline or neuropsychologic* dysfunction or neuropsychologic* tests or neuropsychologic* assessment or neuropsychologic* function or neuropsychologic* evaluation or neuropsychologic* performance or neuropsychologic* change or neuropsychologic* problem or neuropsychologic* outcome or neuropsychologic* sequelae).mp. (62490)
23 | or/1–22 (364408)
24 | Randomized controlled trials as topic/ (82496)
25 | Randomized controlled trial/ (337448)
26 | Random allocation/ (75972)
27 | Double blind method/ (117175)
28 | Single blind method/ (16885)
29 | Clinical trial/ (472549)
30 | Clinical trial, phase i.pt. (12507)
31 | Clinical trial, phase ii.pt. (20105)
32 | Clinical trial, phase iii.pt. (7375)
33 | Clinical trial, phase iv.pt. (759)
34 | Controlled clinical trial.pt. (84963)
35 | Randomized controlled trial.pt. (337448)
36 | Multicenter study.pt. (149119)
37 | Clinical trial.pt. (472549)
38 | exp clinical trials as topic/ (259816)
39 | (clinical adj trial$).tw. (174974)
40 | ((singl$ or doubl$ or treb$ or trip$) adj (blind$3 or mask$3)).tw. (114747)
41 | Randomly allocated.tw. (14024)
42 | (allocated adj2 random$).tw. (16356)
43 | or/24–42 (1021274)
44 | Epidemiologic studies/ (5512)
45 | exp cohort studies/ (1215732)
46 | (cohort adj (study or studies)).tw. (64056)
47 | Cohort analy$.tw. (2848)
48 | (follow up adj (study or studies)).tw. (33441)
49 | (Observational adj (study or studies)).tw. (32538)
50 | Longitudinal.tw. (112860)
51 | or/44–50 (1316456)
52 | Meta analysis/ (36638)
53 | Meta analys$.tw. (41461)
54 | literature review.mp. (35019)
55 | (systematic adj (review or overview)).tw. (30248)
56 | or/52–55 (106130)
57 | 43 or 51 or 56 (2182597)
58 | Case report.tw. (170277)
59 | letter/ (758034)
60 | historical article/ (288506)
61 | addresses/ (4019)
62 | autobiography/ (2675)
63 | Bibliography/ (14862)
64 | Biography/ (156977)
65 | Comment/ (484716)
66 | Editorial/ (307072)
67 | News/ (142112)
68 | or/58–67 (1755076)
69 | 57 not 68 (2085235)
70 | limit 69 to humans (1980119)
71 | limit 70 to yr="1990 -Current" (1694926)
72 | limit 71 to english language (1521263)
73 | limit 72 to ("all infant (birth to 23 months)" or "all child (0 to 18 years)" or "newborn infant (birth to 1 month)" or "infant (1 to 23 months)" or "preschool child (2 to 5 years)" or "child (6 to 12 years)" or "adolescent (13 to 18 years)") (423582)
74 | 72 not 73 (1097681)
75 | exp Myocardial Revascularization/ (75825)
76 | exp percutaneous coronary intervention/ (32327)
77 | Heart bypass, right/ (576)
78 | Coronary revascularization.mp. (4172)
79 | (coronary artery bypass graft or CABG).mp. (14519)
80 | (percutaneous coronary intervention or PCI).mp. (15273)
81 | coronary stent*.mp. (4595)
82 | coronary angioplas*.mp. (11666)
83 | or/75–82 (89913)
84 | 74 and 83 (28370)
85 | exp Endarterectomy, Carotid/ (6306)
86 | (carotid endarterectomy or CEA).mp. (20384)
87 | (carotid artery stenting or CAS).mp. (54374)
88 | carotid surg*.mp. (1111)
89 | or/85–88 (76271)
90 | 74 and 89 (6030)
91 | Heart valve prosthesis/ (26828)
92 | exp Heart Valve Prosthesis Implantation/ (11217)
93 | Cardiac valve annuloplasty/ (137)
94 | (aortic valve replacement or AVR).mp. (8953)
95 | (mitral valve replacement or MVR).mp. (5610)
96 | (aortic valve repair or mitral valve repair).mp. (2378)
97 | (aortic valve surg* or mitral valve surg*).mp. (2156)
98 | or/91–97 (41284)
99 | 74 and 98 (5753)
100 | exp Catheter Ablation/ (18600)
101 | exp Ablation Techniques/ (82421)
102 | 100 or 101 (82421)
103 | exp Atrial Fibrillation/ (30442)
104 | atrial fibrillation ablation.mp. (446)
105 | 103 or 104 (30482)
106 | 102 and 105 (5004)
107 | 74 and 106 (1659)
108 | 23 and 84 (396)
109 | 23 and 90 (112)
110 | 23 and 99 (40)
111 | 23 and 107 (4)
112 | or/108–111 (527)