# Excluded Studies

1 Bypass without missing a beat. The Johns Hopkins medical letter health after 50. 2003;14(11):1-2. 7. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
2 Abildstrom H, et al. Cerebral blood flow and cognitive dysfunction after coronary surgery. Annals of Thoracic Surgery. 2002;73(4):1174-1178. [pmid: 11996259]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
3 Abu-Omar Y, Taggart DP. Off-pump coronary artery bypass grafting. Lancet. 2002;360(9329):327-329. [pmid: 12147389]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
4 Aharon-Peretz J, et al. Cognitive performance following endarterectomy in asymptomatic severe carotid stenosis. European Journal of Neurology. 2003;10(5):525-588. [pmid: 12940834]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
5 Ahlgren E, et al. Neurocognitive impairment and driving performance after coronary artery bypass surgery. European Journal of Cardio-Thoracic Surgery. 2003;23(3):334-340. [pmid: 12614803]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
6 Aldea GS, et al. Effect of anticoagulation protocol on outcome in patients undergoing CABG with heparin-bonded cardiopulmonary bypass circuits. The Annals of thoracic surgery. 1998;65:425-433. [pmid: 9485240]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
7 Aleksic M, et al. Cognitive function remains unchanged after endarterectomy of unilateral internal carotid artery stenosis under local anaesthesia. European Journal of Vascular & Endovascular Surgery. 2006;31(6):616-621. [pmid: 16466939]. POPULATION MEAN AGE <65
8 Al-Ruzzeh S, et al. Effect of off-pump coronary artery bypass surgery on clinical, angiographic, neurocognitive, and quality of life outcomes: randomised controlled trial. BMJ. 2006;332(7554):1365. [pmid: 16740529]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
9 Altinbas A. Silent cerebral infarcts after carotid endarterectomy or stenting and the risk of cognitive decline. Stroke Trials Registry, Internet Stroke Center: www.strokecenter.org/trials/. 2006. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
10 Altinbas A, et al. Silent cerebral infarcts after carotid endarterectomy or stenting and the risk of cognitive decline. A randomized comparison. 17th European Stroke Conference. 2008. DUPLICATE / NOT UNIQUE STUDY
11 Altinbas A, et al. Silent cerebral infarcts after carotid endarterectomy or stenting and the risk of cognitive decline. A randomized comparison. International Stroke Conference 2009. 2009. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
12 Altobelli Iii A, et al. Surgical coronary revascularization in the elderly. American Journal of Geriatric Cardiology. 2002;11(3):157-159. [pmid: 11986527]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
13 Andrew MJ, et al. Mood state as a predictor of neuropsychological deficits following cardiac surgery. Journal of Psychosomatic Research. 2000;48(6):537-546. [pmid: 11033372]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
14 Anon Effect of remote ischemic preconditioning on cognitive function after off-pump coronary artery bypass graft. ClinicalTrials.gov [www.clinicaltrials.gov]. 2009. FULL TEXT UNAVAILABLE
15 Antonelli Incalzi R, et al. Neuropsychologic effects of carotid endarterectomy. Journal of Clinical & Experimental Neuropsychology: Official Journal of the International Neuropsychological Society. 1997;19(6):785-794. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
16 Arrowsmith JE, et al. Central nervous system complications of cardiac surgery. British Journal of Anaesthesia. 2000;84(3):378-393. [pmid: 10793601]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
17 Attigah N, et al. Assessment of patients' satisfaction in carotid surgery under local anaesthesia by psychometrical testing--a prospective cohort study. European Journal of Vascular & Endovascular Surgery. 2011;41(1):76-82. [pmid: 20880727]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
18 Baba T, et al. Early neuropsychological dysfunction in elderly high-risk patients after on-pump and off-pump coronary bypass surgery. Journal of Anesthesia. 2007;21(4):452-458. [pmid: 18008111]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
19 Baikoussis NG, et al. Baseline cerebral oximetry values in cardiac and vascular surgery patients: a prospective observational study. Journal Of Cardiothoracic Surgery. 2010;5:41. [pmid: 20497559]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
20 Baker RA, et al. The Octopus II stabilizing system: biochemical and neuropsychological outcomes in coronary artery bypass surgery. Heart Surgery Forum. Suppl 1. 2001;4:S19-S23. [pmid: 11178303]. POPULATION MEAN AGE <65
21 Baker RA, et al. Preoperative depression and mortality in coronary artery bypass surgery: preliminary findings. ANZ Journal of Surgery. 2001;71(3):139-142. [pmid: 11277141]. NO POST-PROCEDURE MEASURE OF COGNITION
22 Bappu NJ, et al. Troponin-I release after cardiac surgery with different surgical techniques and post-operative neurological outcomes. McGill Journal of Medicine. 2006;9(2):88-94. [pmid: 18523619]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
23 Barber PA, et al. Cerebral ischemic lesions on diffusion-weighted imaging are associated with neurocognitive decline after cardiac surgery. Stroke. 2008;39(5):1427-1433. [pmid: 18323490]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
24 Barnason S, et al. Influence of a symptom management telehealth intervention on older adults' early recovery outcomes after coronary artery bypass surgery. Heart & Lung. 2009;38(5):364-276. [pmid: 19755186]. NO POST-PROCEDURE MEASURE OF COGNITION
25 Barnes DE, et al. Predicting risk of dementia in older adults: The late-life dementia risk index. Neurology. 2009;73(3):173-179. [pmid: 19439724]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
26 Bar-Yosef S, et al. Aortic atheroma burden and cognitive dysfunction after coronary artery bypass graft surgery. Annals of Thoracic Surgery. 2004;78(5):1556-1562. [pmid: 15511430]. NO POST-PROCEDURE MEASURE OF COGNITION
27 Bar-Yosef S, et al. Prevention of cerebral hyperthermia during cardiac surgery by limiting on-bypass rewarming combination with post-bypass body surface warming: A feasibility study. Anesth Analg. 2004;99(3):641-646. [pmid: 15333386]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
28 Bashein G, et al. A randomized study of carbon dioxide management during hypothermic cardiopulmonary bypass. Anesthesiology. 1990;72(1):7-15. [pmid: 2105070]. POPULATION MEAN AGE <65
29 Basile AM, et al. S-100 protein and neuron-specific enolase as markers of subclinical cerebral damage after cardiac surgery: preliminary observation of a 6-month follow-up study. European Neurology. 2001;45(3):151-159. [pmid: 11306858]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
30 Baufreton C, et al. Brain injury and neuropsychological outcome after coronary artery surgery are affected by complement activation. Annals of Thoracic Surgery. 2005;79(5):1597-1605. [pmid: 15854939]. POPULATION MEAN AGE <65
31 Baumgartner WA. Neurocognitive changes after coronary bypass surgery. Circulation. 2007;116(17):1879-1881. [pmid: 17965403]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
32 Beaty CA, et al. The role of head computed tomography imaging in the evaluation of postoperative neurologic deficits in cardiac surgery patients. Annals of Thoracic Surgery. 95(2):548-554. [pmid: 23218967]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
33 Bejjani G, et al. No evidence of memory processing during propofol-remifentanil target-controlled infusion anesthesia with bispectral index monitoring in cardiac surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2009;23(2):175-181. [pmid: 19026570]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
34 Berger K, et al. The association between silent stroke and functional status in an elderly, general population - The MEMO-Study, in Research and Practice in Alzheimer's Disease. 2005:142-146. FULL TEXT UNAVAILABLE
35 Bergh C, et al. In the eye of both patient and spouse: memory is poor 1 to 2 years after coronary bypass and angioplasty. Annals of Thoracic Surgery. 2002;74(3):689-693. discussion 694. [pmid: 12238825]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
36 Bhudia SK, et al. Magnesium as a neuroprotectant in cardiac surgery: a randomized clinical trial.[Erratum appears in J Thorac Cardiovasc Surg. 2007 Aug;134(2)25A]. Journal of Thoracic & Cardiovascular Surgery. 2006;131(4):853-861. [pmid: 16580444]. POPULATION MEAN AGE <65
37 Bo M, et al. Risk of cognitive decline in older patients after carotid endarterectomy: an observational study. Journal of the American Geriatrics Society. 2006;54(6):932-936. [pmid: 16776788]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
38 Bokeriia LA, et al. Asymmetric cerebral embolic load and postoperative cognitive dysfunction in cardiac surgery. Cerebrovascular Diseases. 2007;23(1):50-56. [pmid: 16968987]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
39 Bokesch PM, et al. NMDA receptor antibodies predict adverse neurological outcome after cardiac surgery in high-risk patients. Stroke. 2006;37(6):1432-1436. [pmid: 16627793]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
40 Boodhwani M, et al. Predictors of early neurocognitive deficits in low-risk patients undergoing on-pump coronary artery bypass surgery. Circulation. 2006;114(1 Suppl):I461-I466. [pmid: 16820619]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
41 Borger MA, et al. Neuropsychologic impairment after coronary bypass surgery: effect of gaseous microemboli during perfusionist interventions. Journal of Thoracic & Cardiovascular Surgery. 2001;121(4):743-749. [pmid: 11279417]. POPULATION MEAN AGE <65
42 Borger MA, Rao V. Temperature management during cardiopulmonary bypass: Effect of rewarming rate on cognitive dysfunction. Seminars in Cardiothoracic and Vascular Anesthesia. 2002;6(1):17-20. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
43 Borroni B, et al. Is mild vascular cognitive impairment reversible? Evidence from a study on the effect of carotid endarterectomy. Neurological Research. 2004;26(5):594-597. [pmid: 15265280]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
44 Bossema E, et al. Testing the laterality hypothesis after left or right carotid endarterectomy: no ipsilateral effects on neuropsychological functioning. Journal of Clinical & Experimental Neuropsychology: Official Journal of the International Neuropsychological Society. 2007;29(5):505-513. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
45 Bossema ER, et al. Does carotid endarterectomy improve cognitive functioning?. Journal of Vascular Surgery. 2005;41(5):775-781. discussion 781. [pmid: 15886659]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
46 Bossema ER, et al. Perioperative microembolism is not associated with cognitive outcome three months after carotid endarterectomy. European Journal of Vascular & Endovascular Surgery. 2005;29(3):262-268. [pmid: 15694799]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
47 Bowler JV, Gorelick PB. Advances in vascular cognitive impairment. Stroke. 2009;40(5):e315-e318. [pmid: 19359630]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
48 Brækken SK, et al. Association between intraoperative cerebral microembolic signals and postoperative neuropsychological deficit: Comparison between patients with cardiac valve replacement and patients with coronary artery bypass grafting. Journal of Neurology Neurosurgery and Psychiatry. 1998;65(4):573-576. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
49 Brand N, et al. Left or right carotid endarterectomy in patients with atherosclerotic disease: ipsilateral effects on cognition?. Brain & Cognition. 2004;54(2):117-123. [pmid: 14980452]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
50 Brillman J, et al. Increased middle cerebral artery flow velocity during the initial phase of cardiopulmonary bypass may cause neurological dysfunction. Journal of Neuroimaging. 1995;5(3):135-141. [pmid: 7626819]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
51 Browndyke JN, et al. Acute neuropsychological functioning following cardiosurgical interventions associated with the production of intraoperative cerebral microemboli. Clinical Neuropsychologist. 2002;16(4):463-471. [pmid: 12822055]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
52 Browne SM, et al. Cognitive performance after cardiac operation: implications of regression toward the mean. Journal of Thoracic & Cardiovascular Surgery. 1999;117(3):481-485. [pmid: 10047650]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
53 Bruggemans EF, Van Dijk JG, Huysmans HA. Residual cognitive dysfunctioning at 6 months following coronary artery bypass graft surgery. European Journal of Cardio-Thoracic Surgery. 1995;9(11):636-643. [pmid: 8751253]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
54 Bucerius J, et al. Predictors of delirium after cardiac surgery delirium: Effect of beating-heart (off-pump) surgery. Journal of Thoracic and Cardiovascular Surgery. 2004;127(1):57-64. [pmid: 14752413]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
55 Bunch TJ, et al. Patients treated with catheter ablation for atrial fibrillation have long-term rates of death, stroke, and dementia similar to patients without atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2011;22(8):839-845. [pmid: 21410581]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
56 Burker EJ, et al. The Mini Mental State Exam as a predictor of neuropsychological functioning after cardiac surgery. International Journal of Psychiatry in Medicine. 1995;25(3):263-276. [pmid: 8567193]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
57 Busch T, et al. Combined approach for internal carotid artery stenosis and cardiovascular disease in septuagenarians--a comparative study. European Journal of Cardio-Thoracic Surgery. 1999;16(6):602-606. [pmid: 10647827]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
58 Buschbeck D, et al. Short-term neuropsychologic differences after normothermic versus hypothermic cardiopulmonary bypass. Journal of Thoracic & Cardiovascular Surgery. 1998;116(2):350-353. [pmid: 9699590]. POPULATION MEAN AGE <65
59 Butterworth J, et al. Attempted control of hyperglycemia during cardiopulmonary bypass fails to improve neurologic or neurobehavioral outcomes in patients without diabetes mellitus undergoing coronary artery bypass grafting. Journal of Thoracic and Cardiovascular Surgery. 2005;130(5):1319.e1-1319.e9. [pmid: 16256784]. POPULATION MEAN AGE <65
60 Buziashvili YI, et al. Use of P300 cognitive evoked potentials in the diagnosis of impairments of higher mental functions after cardiac surgery in conditions of cardiopulmonary bypass. Neuroscience and Behavioral Physiology. 2006;36(2):115-118. [pmid: 16380824]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
61 Camboni D, et al. Microbubble activity in miniaturized and in conventional extracorporeal circulation. ASAIO Journal. 2009;55(1):58-62. [pmid: 19092669]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
62 Capoccia L, et al. Silent stroke and cognitive decline in asymptomatic carotid stenosis revascularization. Vascular. 2012;20(4):181-187. [pmid: 22734086]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
63 Capoccia L, et al. Comparative study on carotid revascularization (endarterectomy vs stenting) using markers of cellular brain injury, neuropsychometric tests, and diffusion-weighted magnetic resonance imaging. Journal of Vascular Surgery. 2010;51(3):584-591. 591.e1. 591.e3. discussion 592. [pmid: 20045614]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
64 Carroll DL. The importance of self-efficacy expectations in elderly patients recovering from coronary artery bypass surgery. Heart & Lung. 1995;24(1):50-59. [pmid: 7706100]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
65 Casey C, Faxon DP. Multi-vessel coronary disease percutaneous coronary intervention. Heart. 2004;90(3):341-346. [pmid: 14966067]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
66 Charlson ME, et al. Improvement of outcomes after coronary artery bypass II: a randomized trial comparing intraoperative high versus customized mean arterial pressure. Journal of Cardiac Surgery. 2007;22(6):465-472. [pmid: 18039205]. POPULATION MEAN AGE <65
67 Chen J, Yan J, Han X. Dexmedetomidine may benefit cognitive function after laparoscopic cholecystectomy in elderly patients. Experimental and Therapeutic Medicine. 5(2):489-494. [pmid: 23403854]. NOT TREATED WITH CV PROCEDURE OF INTEREST
68 Cheng DC, et al. Morbidity outcome in early versus conventional tracheal extubation after coronary artery bypass grafting: a prospective randomized controlled trial. Journal of Thoracic & Cardiovascular Surgery. 1996;112(3):755-764. [pmid: 8800165]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
69 Chernov VI, et al. Short-term and long-term cognitive function and cerebral perfusion in off-pump and on-pump coronary artery bypass patients. European Journal of Cardio-thoracic Surgery. 2006;29(1):74-81. [pmid: 16337804]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
70 Chong SY, et al. Deep hypothermic circulatory arrest in adults undergoing aortic surgery: Local experience. Annals of the Academy of Medicine Singapore. 2004;33(3):289-293. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
71 Chuang YM, et al. Immediate regression of leukoaraiosis after carotid artery revascularization. Cerebrovascular Diseases. 32(5):439-446. [pmid: 22005278]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
72 Cicekcioglu F, et al. Neurocognitive functions after beating heart mitral valve replacement without cross-clamping the aorta. Journal of Cardiac Surgery. 2008;23(2):114-119. [pmid: 18304124]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
73 Clark RE, et al. Microemboli during coronary artery bypass grafting. Genesis and effect on outcome. Journal of Thoracic & Cardiovascular Surgery. 1995;109(2):249-257. discussion 257–8. [pmid: 7853878]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
74 Cook DJ, et al. Postcardiac surgical cognitive impairment in the aged using diffusion-weighted magnetic resonance imaging. Annals of Thoracic Surgery. 2007;83(4):1389-1395. [pmid: 17383345]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
75 Cormack F, Shipolini A, Awad WI, et al. A meta-analysis of cognitive outcome following coronary artery bypass graft surgery. Neurosci Biobehav Rev. Oct. 2012;36(9):2118-2129. [pmid: 22732162]. POPULATION MEAN AGE <65
76 Czerny M, et al. Sustained cognitive benefit 5 years after carotid endarterectomy. Journal of Vascular Surgery. 2010;51(5):1139-1144. [pmid: 20299177]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
77 David Hillis L, et al. 2011 ACCF/AHA guideline for coronary artery bypass graft surgery a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. Circulation. 124(23):e652-e735. [pmid: 22064599]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
78 de Tournay-Jette E, et al. The relationship between cerebral oxygen saturation changes and postoperative cognitive dysfunction in elderly patients after coronary artery bypass graft surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2011;25(1):95-104. [pmid: 20650659]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
79 de Tournay-Jette E, et al. The benefits of cognitive training after a coronary artery bypass graft surgery. Journal of Behavioral Medicine. 2012;35(5):557-568. [pmid: 22068879]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
80 Deklunder G, et al. Microemboli in cerebral circulation and alteration of cognitive abilities in patients with mechanical prosthetic heart valves. Stroke. 1998;29(9):1821-1826. [pmid: 9731602]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
81 Detroyer E, et al. Is preoperative anxiety and depression associated with onset of delirium after cardiac surgery in older patients? A prospective cohort study. J Am Geriatr Soc. 2008;56(12):2278-2284. [pmid: 19112653]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
82 Di Carlo A, et al. Clinically relevant cognitive impairment after cardiac surgery: A 6-month follow-up study. J Neurol Sci. 2001;188(1–2):85-93. [pmid: 11489290]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
83 Diegeler A, et al. Neuromonitoring and neurocognitive outcome in off-pump versus conventional coronary bypass operation. Annals of Thoracic Surgery. 2000;69(4):1162-1166. [pmid: 10800812]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
84 Dieleman J, et al. Presence of coronary collaterals is associated with a decreased incidence of cognitive decline after coronary artery bypass surgery. European Journal of Cardio-Thoracic Surgery. 2009;35(1):48-53. [pmid: 19027312]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
85 DiMaria-Ghalili RA. Changes in nutritional status and postoperative outcomes in elderly CABG patients.[Erratum appears in Biol Res Nurs. 2004 Oct;6(2)158]. Biological Research for Nursing. 2002;4(2):73-84. [pmid: 12408213]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
86 DiSesa VJ. Patient characteristics can predict improvement in functional health after elective coronary artery bypass grafting. Annals of Thoracic Surgery. 2003;75(6):1855. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
87 Djaiani GN, et al. Chronic exposure to nicotine does not prevent neurocognitive decline after cardiac surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2003;17(3):341-345. [pmid: 12827583]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
88 Dogan S, et al. Minimally invasive port access versus conventional mitral valve surgery: prospective randomized study. Annals of Thoracic Surgery. 2005;79(2):492-498. [pmid: 15680822]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
89 Dogan S, et al. Minimally invasive versus conventional aortic valve replacement: a prospective randomized trial. Journal of Heart Valve Disease. 2003;12(1):76-80. [pmid: 12578340]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
90 Dogan S, et al. How safe is the port access technique in minimally invasive coronary artery bypass grafting?. The Annals of thoracic surgery. 2002;74:1537-1543. discussion 1543. [pmid: 12440605]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
91 Doraiswamy PM, et al. Donepezil for cognitive decline following coronary artery bypass surgery: a pilot randomized controlled trial. Psychopharmacology Bulletin. 2007;40(2):54-62. [pmid: 17514186]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
92 Dowd NP, et al. Fast-track cardiac anaesthesia in the elderly: effect of two different anaesthetic techniques on mental recovery. British Journal of Anaesthesia. 2001;86(1):68-76. [pmid: 11575413]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
93 Dumas A, et al. Early versus late extubation after coronary artery bypass grafting: effects on cognitive function. Journal of Cardiothoracic & Vascular Anesthesia. 1999;13(2):130-135. [pmid: 10230943]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
94 Dupuis G, et al. Coronary artery bypass graft surgery and cognitive performance. American Journal of Critical Care. 2006;15(5):471-478. quiz 479. [pmid: 16926368]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
95 Ebert AD, et al. Early neurobehavioral disorders after cardiac surgery: a comparative analysis of coronary artery bypass graft surgery and valve replacement. Journal of Cardiothoracic & Vascular Anesthesia. 2001;15(1):15-19. [pmid: 11254833]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
96 Eifert S, et al. Neurological and neuropsychological examination and outcome after use of an intra-aortic filter device during cardiac surgery. Perfusion. SUPPL 1. 2003;18:55-60. [pmid: 12708766]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
97 Engelhardt W, et al. Early cerebral functional outcome after coronary artery bypass surgery using different acid-base management during hypothermic cardiopulmonary bypass. Acta Anaesthesiologica Scandinavica. 1996;40(4):457-465. [pmid: 8738691]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
98 Engelman RM, et al. Is there a relationship between systemic perfusion temperature during coronary artery bypass grafting and extent of intraoperative ischemic central nervous system injury?. The Journal of thoracic and cardiovascular surgery. 2000;119:230-232. [pmid: 10649197]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
99 Engelman RM, et al. Does cardiopulmonary bypass temperature correlate with postoperative central nervous system dysfunction?. Journal of Cardiac Surgery. 1995;10(4 Suppl):493-497. [pmid: 7579848]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
100 Engelman RM, et al. Influence of cardiopulmonary bypass perfusion temperature on neurologic and hematologic function after coronary artery bypass grafting. Annals of Thoracic Surgery. 1999;67(6):1547-1555. discussion 1556. [pmid: 10391253]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
101 Ernest CS, et al. Predictors of cognitive function in candidates for coronary artery bypass graft surgery. Journal of the International Neuropsychological Society. 2007;13(2):257-266. [pmid: 17286883]. POPULATION MEAN AGE <65
102 Ernest CS, et al. Cognitive function in candidates for coronary artery bypass graft surgery. Annals of Thoracic Surgery. 2006;82(3):812-818. [pmid: 16928490]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
103 Evered L, et al. Postoperative cognitive dysfunction is independent of type of surgery and anesthetic. Anesthesia & Analgesia. 2011;112(5):1179-1185. [pmid: 21474666]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
104 Fan XC, et al. Cognitive function in congenital heart disease after cardiac surgery with extracorporeal circulation. World Journal of Pediatrics. 6(3):268-270. [pmid: 20119874]. POPULATION MEAN AGE <65
105 Farsak B, et al. Elevated levels of s-100β correlate with neurocognitive outcome after cardiac surgery. Journal of Cardiovascular Surgery. 2003;44(1):31-35. [pmid: 12627069]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
106 Fearn SJ, et al. Carotid endarterectomy improves cognitive function in patients with exhausted cerebrovascular reserve. European Journal of Vascular & Endovascular Surgery. 2003;26(5):529-536. [pmid: 14532882]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
107 Fearn SJ, et al. Cerebral injury during cardiopulmonary bypass: emboli impair memory. Journal of Thoracic & Cardiovascular Surgery. 2001;121(6):1150-1160. [pmid: 11385383]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
108 Feliziani FT, et al. Cognitive performance in elderly patients undergoing carotid endarterectomy or carotid artery stenting: a twelve-month follow-up study. Cerebrovascular Diseases. 2010;30(3):244-251. [pmid: 20664257]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
109 Fiedler J, et al. Cognitive outcome after EC-IC bypass surgery in hemodynamic cerebral ischemia. Acta Neurochirurgica. 153(6):1303-1311. [pmid: 21298453]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
110 Floyd TF, et al. Clinically silent cerebral ischemic events after cardiac surgery: their incidence, regional vascular occurrence, and procedural dependence. Annals of Thoracic Surgery. 2006;81(6):2160-2166. [pmid: 16731147]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
111 Fontanella M, et al. Neuropsychological assessment after microsurgical clipping or endovascular treatment for anterior communicating artery aneurysm. Acta Neurochirurgica. 2003;145(10):867-872. [pmid: 14577008]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
112 Freedland KE, et al. Treatment of depression after coronary artery bypass surgery: a randomized controlled trial. Archives of General Psychiatry. 2009;66(4):387-396. [pmid: 19349308]. POPULATION MEAN AGE <65
113 Friedlander R. A study of the effects of minocycline on cognitive function after carotid endarterectomy. ClinicalTrials.gov. 2006. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
114 Fukunaga S, et al. Neuropsychological changes in patients with carotid stenosis after carotid endarterectomy. European Neurology. 2006;55(3):145-150. [pmid: 16682798]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
115 Gallagher R, McKinley S. Anxiety, depression and perceived control in patients having coronary artery bypass grafts. Journal of Advanced Nursing. 2009;65(11):2386-2396. [pmid: 19747294]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
116 Gerriets T, et al. Evaluation of methods to predict early long-term neurobehavioral outcome after coronary artery bypass grafting. American Journal of Cardiology. 2010;105(8):1095-1101. [pmid: 20381659]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
117 Gerriets T, et al. Protecting the brain from gaseous and solid micro-emboli during coronary artery bypass grafting: a randomized controlled trial. European Heart Journal. 2010;31(3):360-368. [pmid: 19541675]. NO POST-PROCEDURE MEASURE OF COGNITION
118 Gold JP, et al. Improving outcomes in coronary surgery: the impact of echo-directed aortic cannulation and perioperative hemodynamic management in 500 patients. Annals of Thoracic Surgery. 2004;78(5):1579-1585. [pmid: 15511435]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
119 Gossetti B, et al. Embolism to the brain during carotid stenting and surgery. Acta Chirurgica Belgica. 2007;107(2):151-154. [pmid: 17515263]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
120 Goto T, et al. Magnetic resonance imaging findings and postoperative neurologic dysfunction in elderly patients undergoing coronary artery bypass grafting. Annals of Thoracic Surgery. 2001;72(1):137-142. [pmid: 11465168]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
121 Goto T, et al. Gender differences in stroke risk among the elderly after coronary artery surgery. Anesthesia and Analgesia. 2007;104(5):1016-1022. [pmid: 17456646]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
122 Gottesman RF, et al. Early postoperative cognitive dysfunction and blood pressure during coronary artery bypass graft operation. Archives of Neurology. 2007;64(8):1111-1114. [pmid: 17562924]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
123 Gremigni P, Sciarroni L, Pedrini L. Cognitive changes after carotid endarterectomy. Monaldi Archives for Chest Disease. 2009;72(2):91-97. [pmid: 19947191]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
124 Grieco G, et al. Evaluating neuroprotective agents for clinical anti-ischemic benefit using neurological and neuropsychological changes after cardiac surgery under cardiopulmonary bypass. Methodological strategies and results of a double-blind, placebo-controlled trial of GM1 ganglioside. Stroke. 1996;27(5):858-874. [pmid: 8623106]. POPULATION MEAN AGE <65
125 Griffin S, et al. The effect of substrate load and blood glucose management on cerebral dysfunction following cardiopulmonary bypass. Vasc Surg. 1992;26:656-664. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
126 Grigore AM, et al. The rewarming rate and increased peak temperature alter neurocognitive outcome after cardiac surgery. Anesthesia & Analgesia. 2002;94(1):4-10. [pmid: 11772792]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
127 Grigore AM, et al. Prospective randomized trial of normothermic versus hypothermic cardiopulmonary bypass on cognitive function after coronary artery bypass graft surgery. Anesthesiology. 2001;95(5):1110-1119. [pmid: 11684979]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
128 Grimm M, et al. Normothermic cardiopulmonary bypass is beneficial for cognitive brain function after coronary artery bypass grafting--a prospective randomized trial. European Journal of Cardio-Thoracic Surgery. 2000;18(3):270-275. [pmid: 10973534]. POPULATION MEAN AGE <65
129 Grimm M, et al. Neurocognitive deficit following mitral valve surgery. European Journal of Cardio-Thoracic Surgery. 2003;23(3):265-271. [pmid: 12614792]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
130 Gunaydin B, Babacan A. Cerebral hypoperfusion after cardiac surgery and anesthetic strategies: a comparative study with high dose fentanyl and barbiturate anesthesia. Annals of thoracic and cardiovascular surgery : official journal of the Association of Thoracic and Cardiovascular Surgeons of Asia. 1998;4:12-17. POPULATION MEAN AGE <65
131 Haeusler KG, et al. 3 Tesla MRI-detected brain lesions after pulmonary vein isolation for atrial fibrillation: Results of the MACPAF study. J Cardiovasc Electrophysiol. 24(1):14-21. [pmid: 22913568]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
132 Haeusler KG, et al. Stroke risk associated with balloon based catheter ablation for atrial fibrillation: Rationale and design of the MACPAF Study. BMC Neurology. 2010;10:63. [pmid: 20663131]. POPULATION MEAN AGE <65
133 Haley AP, et al. Verbal working memory and atherosclerosis in patients with cardiovascular disease: An fMRI study. Journal of Neuroimaging. 2007;17(3):227-233. [pmid: 17608908]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
134 Hammon JW, et al. Single crossclamp improves 6-month cognitive outcome in high-risk coronary bypass patients: the effect of reduced aortic manipulation. Journal of Thoracic & Cardiovascular Surgery. 2006;131(1):114-121. [pmid: 16399302]. POPULATION MEAN AGE <65
135 Hammon JW, et al. Coronary artery bypass grafting with single cross-clamp results in fewer persistent neuropsychological deficits than multiple clamp or off-pump coronary artery bypass grafting. Annals of Thoracic Surgery. 2007;84(4):1174-1178. discussion 1178–9. [pmid: 17888966]. POPULATION MEAN AGE <65
136 Harmon D, et al. Plasma concentrations of nitric oxide products and cognitive dysfunction following coronary artery bypass surgery. European Journal of Anaesthesiology. 2005;22(4):269-276. [pmid: 15892404]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
137 Hegland D, et al. Cerebral magnetic resonance findings in asymptomatic patients after atrial fibrillation catheter ablation: Cause for alarm or further study?. J Cardiovasc Electrophysiol. 22(9):969-972. [pmid: 21635614]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
138 Helgeson VS. Cognitive adaptation, psychological adjustment, and disease progression among angioplasty patients: 4 years later. Health Psychology. 2003;22(1):30-38. [pmid: 12558199]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
139 Henze T, Stephan H, Sonntag H. Cerebral dysfunction following extracorporeal circulation for aortocoronary bypass surgery: no differences in neuropsychological outcome after pulsatile versus nonpulsatile flow. Thoracic & Cardiovascular Surgeon. 1990;38(2):65-68. [pmid: 2349553]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
140 Hernandez F Jr, et al. Neurocognitive outcomes of off-pump versus on-pump coronary artery bypass: a prospective randomized controlled trial. Annals of Thoracic Surgery. 2007;84(6):1897-1903. [pmid: 18036904]. POPULATION MEAN AGE <65
141 Herrmann M, et al. A contrastive analysis of release patterns of biochemical markers of brain damage after coronary artery bypass grafting and valve replacement and their association with the neurobehavioral outcome after cardiac surgery. European Journal of Cardio-Thoracic Surgery. 1999;16(5):513-518. [pmid: 10609901]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
142 Heyer EJ, et al. Cerebral dysfunction after coronary artery bypass grafting done with mild or moderate hypothermia. Journal of Thoracic & Cardiovascular Surgery. 1997;114(2):270-277. [pmid: 9270646]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
143 Heyer EJ, et al. Neuropsychometric changes in patients after carotid endarterectomy. Stroke. 1998;29(6):1110-1115. [pmid: 9626280]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
144 Heyer EJ, et al. A study of cognitive dysfunction in patients having carotid endarterectomy performed with regional anesthesia. Anesthesia & Analgesia. 2008;107(2):636-642. [pmid: 18633045]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
145 Heyer EJ, et al. Heparin-bonded cardiopulmonary bypass circuits reduce cognitive dysfunction. Journal of Cardiothoracic & Vascular Anesthesia. 2002;16(1):37-42. [pmid: 11854876]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
146 Heyer EJ, et al. A controlled prospective study of neuropsychological dysfunction following carotid endarterectomy. Archives of Neurology. 2002;59(2):217-222. [pmid: 11843692]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
147 Heyer EJ, et al. APOE-epsilon4 predisposes to cognitive dysfunction following uncomplicated carotid endarterectomy. Neurology. 2005;65(11):1759-1763. [pmid: 16207841]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
148 Hickey PR. Neurologic sequelae associated with deep hypothermic circulatory arrest. Annals of Thoracic Surgery. 1998;65(6 SUPPL.):S65-S70. [pmid: 9647142]. POPULATION MEAN AGE <65
149 Hlatky MA, et al. Cognitive function 5 years after randomization to coronary angioplasty or coronary artery bypass graft surgery. Circulation. 1997;96(9 Suppl):II-11-II-14. discussion II-15. POPULATION MEAN AGE <65
150 Ho PM, et al. Predictors of cognitive decline following coronary artery bypass graft surgery. Annals of Thoracic Surgery. 2004;77(2):597-603. discussion 603. [pmid: 14759444]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
151 Hogue CW, et al. Risk Factors for Neurocognitive Dysfunction After Cardiac Surgery in Postmenopausal Women. Annals of Thoracic Surgery. 2008;86(2):511-516. [pmid: 18640325]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
152 Huang K-L, et al. Impact of silent ischemic lesions on cognition following carotid artery stenting. European Neurology. 2011;66(6):351-358. [pmid: 22123044]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
153 Hudetz JA, et al. Postoperative delirium and short-term cognitive dysfunction occur more frequently in patients undergoing valve surgery with or without coronary artery bypass graft surgery compared with coronary artery bypass graft surgery alone: Results of a pilot study. J Cardiothorac Vasc Anesth. 25(5):811-816. [pmid: 20655248]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
154 Hudetz JA, et al. Metabolic syndrome exacerbates short-term postoperative cognitive dysfunction in patients undergoing cardiac surgery: Results of a pilot study. Journal of Cardiothoracic and Vascular Anesthesia. 25(2):282-287. [pmid: 20728380]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
155 Hudetz JA, Patterson KM, Pagel PS. Comparison of pre-existing cognitive impairment, amnesic mild cognitive impairment, and multiple domain mild cognitive impairment in men scheduled for coronary artery surgery. European Journal of Anaesthesiology. 2012;29(7):320-325. [pmid: 22569024]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
156 Isgro F, et al. A predictive parameter in patients with brain related complications after cardiac surgery?. European Journal of Cardio-Thoracic Surgery. 1997;11(4):640-644. [pmid: 9151030]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
157 Ishihara H, et al. Cognitive outcome differences on the side of carotid artery stenting. Journal of Vascular Surgery. 2013;57(1):125-130. [pmid: 23141681]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
158 Iskesen I, et al. Opening the cardiac chambers does not make any difference in p300 measurement. Heart Surgery Forum. 2006;9(5):E770-E773. [pmid: 16844636]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
159 Jansen C, et al. Cognitive functions after surgery or stenting in extracranial stenosis of the carotid artery. Stroke. 2009;40:e175. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
160 Johnston SC, et al. Cognitive impairment and decline are associated with carotid artery disease in patients without clinically evident cerebrovascular disease. Annals of Internal Medicine. 2004;140(4):237-247. [pmid: 14970146]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
161 Kadoi Y, Goto F. Factors associated with postoperative cognitive dysfunction in patients undergoing cardiac surgery. Surgery Today. 2006;36(12):1053-1057. [pmid: 17123132]. POPULATION MEAN AGE <65
162 Kadoi Y, Saito S, Fujita N, et al. Effects of balloon-induced pulsatile perfusion on postoperative short- and long-term cognitive dysfunction in diabetic patients with impaired cerebrovascular carbon dioxide reactivity. J Cardiothorac Vasc Anesth. Apr. 2013;27(2):238-244. [pmid: 23063103]. POPULATION MEAN AGE <65
163 Kadoi Y, et al. Slow rewarming has no effects on the decrease in jugular venous oxygen hemoglobin saturation and long-term cognitive outcome in diabetic patients. Anesthesia & Analgesia. 2002;94(6):1395-1401. table of contents. [pmid: 12031995]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
164 Kadoi Y, et al. Jugular venous oxygen saturation during mild hypothermic versus normothermic cardiopulmonary bypass in elderly patients. Surgery Today. 2004;34(5):399-404. [pmid: 15108076]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
165 Kahlert P, et al. Silent and apparent cerebral ischemia after percutaneous transfemoral aortic valve implantation: A diffusion-weighted magnetic resonance imaging study. Circulation. 121(7):870-878. [pmid: 20177005]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
166 Kapetanakis EI, et al. The impact of aortic manipulation on neurologic outcomes after coronary artery bypass surgery: a risk-adjusted study. Annals of Thoracic Surgery. 2004;78(5):1564-1571. [pmid: 15511432]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
167 Kapetanakis EI, et al. Comparison of the quality of life after conventional versus off-pump coronary artery bypass surgery. Journal of Cardiac Surgery. 2008;23(2):120-125. [pmid: 18304125]. NO POST-PROCEDURE MEASURE OF COGNITION
168 Kapur A, et al. The Coronary Artery Revascularisation in Diabetes (CARDia) trial: Background, aims, and design. American Heart Journal. 2005;149(1):13-19. [pmid: 15660030]. NO POST-PROCEDURE MEASURE OF COGNITION
169 Karhunen JP, et al. Long-term survival and quality of life after cardiac resuscitation following coronary artery bypass grafting. European Journal of Cardio-Thoracic Surgery. 2011;40(1):249-254. [pmid: 21168340]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
170 Kassaian SE, et al. A novel scoring system for identifying high-risk patients undergiong carotid stenting. Archives of Iranian Medicine. 2006;9(2):129-137. [pmid: 16649355]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
171 Kaukinen L, et al. Release of brain-specific creatine kinase and neuron-specific enolase into cerebrospinal fluid after hypothermic and normothermic cardiopulmonary bypass in coronary artery surgery. Acta Anaesthesiologica Scandinavica. 2000;44(4):361-368. [pmid: 10757566]. POPULATION MEAN AGE <65
172 Kaukuntla H, et al. Differential brain and body temperature during cardiopulmonary bypass--a randomised clinical study. European Journal of Cardio-Thoracic Surgery. 2004;26(3):571-579. [pmid: 15302053]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
173 Kazmierski J, et al. Preoperative predictors of delirium after cardiac surgery: a preliminary study. General Hospital Psychiatry. 2006;28(6):536-538. [pmid: 17088170]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
174 Keary TA, et al. Blood pressure variability and dementia rating scale performance in older adults with cardiovascular disease. Cognitive and Behavioral Neurology. 2007;20(1):73-77. [pmid: 17356348]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
175 Keizer AMA, et al. Cognitive self-assessment one year after on-pump and off-pump coronary artery bypass grafting. Annals of Thoracic Surgery. 2003;75(3):835-838. discussion 838–9. [pmid: 12645703]. POPULATION MEAN AGE <65
176 Kennedy ED, Choy KC, Alston RP, et al. Cognitive outcome after on- and off-pump coronary artery bypass grafting surgery: a systematic review and meta-analysis. J Cardiothorac Vasc Anesth. Apr. 2013;27(2):253-265. [pmid: 23507014]. POPULATION MEAN AGE <65
177 Kervan U, et al. Comparison of neurocognitive functions after beating-heart mitral valve replacement without aorta cross-clamping and after standard mitral valve replacement with cardioplegic arrest. Heart Surgery Forum. 14(6):E335-E339. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
178 Khosravi A, et al. Evaluation of coated oxygenators in cardiopulmonary-bypass systems and their impact on neurocognitive function. Perfusion. 2005;20(5):249-254. [pmid: 16231620]. POPULATION MEAN AGE <65
179 Khoueiry G, et al. Depression, disability, and quality of life after off-pump coronary artery bypass grafting: a prospective 9-month follow-up study. Heart & Lung. 2011;40(3):217-225. [pmid: 20561876]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
180 Kilminster S, et al. Neuropsychological change and S-100 protein release in 130 unselected patients undergoing cardiac surgery. Stroke. 1999;30(9):1869-1874. [pmid: 10471438]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
181 Kilo J, et al. Cardiopulmonary bypass affects cognitive brain function after coronary artery bypass grafting. Annals of Thoracic Surgery. 2001;72(6):1926-1932. [pmid: 11789773]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
182 Knipp SC, et al. Small ischemic brain lesions after cardiac valve replacement detected by diffusion-weighted magnetic resonance imaging: relation to neurocognitive function. European Journal of Cardio-Thoracic Surgery. 2005;28(1):88-96. [pmid: 15922616]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
183 Knipp SC, et al. Cognitive outcomes three years after coronary artery bypass surgery: relation to diffusion-weighted magnetic resonance imaging. Annals of Thoracic Surgery. 2008;85(3):872-879. [pmid: 18291160]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
184 Knopman DS, et al. Coronary artery bypass grafting is not a risk factor for dementia or Alzheimer disease. Neurology. 2005;65(7):986-990. [pmid: 16217048]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
185 Kobayashi J, et al. Early outcome of a randomized comparison of off-pump and on-pump multiple arterial coronary revascularization. Circulation. 2005;112(9 Suppl):I338-I343. [pmid: 16159843]. NO POST-PROCEDURE MEASURE OF COGNITION
186 Komotar RJ, Heyer EJ, Connolly ES Jr. Cognitive outcomes after carotid revascularization: The role of cerebral emboli and hypoperfusion - Commentary. Neurosurgery. 2008;62(2):393-394. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
187 Kozora E, et al. Cognitive outcomes after on- versus off-pump coronary artery bypass surgery. Annals of Thoracic Surgery. 2010;90(4):1134-1141. [pmid: 20868803]. POPULATION MEAN AGE <65
188 Krone RJ, et al. Ad hoc percutaneous coronary interventions in patients with stable coronary artery disease--a study of prevalence, safety, and variation in use from the American College of Cardiology National Cardiovascular Data Registry (ACC-NCDR). Catheterization & Cardiovascular Interventions. 2006;68(5):696-703. [pmid: 17039514]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
189 Kumar RA, et al. Predictive value of IL-18 and SC5b-9 for neurocognitive dysfunction after cardiopulmonary bypass. British Journal of Anaesthesia. 2007;98(3):317-322. [pmid: 17227817]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
190 Lal BK, et al. Cognitive changes after surgery vs stenting for carotid artery stenosis. Journal of Vascular Surgery. 2011;54(3):691-698. [pmid: 21700413]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
191 Lamy A, et al. Rationale and design of the coronary artery bypass grafting surgery off or on pump revascularization study: A large international randomized trial in cardiac surgery. Am Heart J. 163(1):1-6. [pmid: 22172429]. NO POST-PROCEDURE MEASURE OF COGNITION
192 Lazibat I, et al. Predictors of short-term neurocognitive outcome following coronary revascularisation (CABG) depending on the use of cardiopulmonary bypass. Collegium Antropologicum. 2012;36(3):827-833. [pmid: 23213940]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
193 Lee GA. Determinants of quality of life five years after coronary artery bypass graft surgery. Heart & Lung. 2009;38(2):91-99. [pmid: 19254627]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
194 Lee TA, et al. Assessment of the emergence of Alzheimer's disease following coronary artery bypass graft surgery or percutaneous transluminal coronary angioplasty. Journal of Alzheimer's Disease. 2005;7(4):319-324. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
195 Lee WH, et al. Effects of extracorporeal circulation upon behavior, personality, and brain function. II. Hemodynamic, metabolic, and psychometric correlations. Annals of surgery. 1971;173:1013-1023. [pmid: 5578794]. POPULATION MEAN AGE <65
196 Lelis RGB, et al. Apolipoprotein E4 genotype increases the risk of postoperative cognitive dysfunction in patients undergoing coronary artery bypass graft surgery. Journal of Cardiovascular Surgery. 2006;47(4):451-456. [pmid: 16953165]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
197 Lewis MS, et al. Detection of postoperative cognitive decline after coronary artery bypass graft surgery is affected by the number of neuropsychological tests in the assessment battery. Annals of Thoracic Surgery. 2006;81(6):2097-2104. [pmid: 16731137]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
198 Lewis MS, et al. The sensitivity and specificity of three common statistical rules for the classification of post-operative cognitive dysfunction following coronary artery bypass graft surgery. Acta Anaesthesiologica Scandinavica. 2006;50(1):50-57. [pmid: 16451151]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
199 Lewis MS, et al. The influence of different error estimates in the detection of postoperative cognitive dysfunction using reliable change indices with correction for practice effects.[Republished from Arch Clin Neuropsychol. 2006 Aug;21(5)421–7; PMID:16859888]. Archives of Clinical Neuropsychology. 2007;22(2):249-257. [pmid: 17443923]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
200 Lewis MS, Maruff PT, Silbert BS. Examination of the use of cognitive domains in postoperative cognitive dysfunction after coronary artery bypass graft surgery. Annals of Thoracic Surgery. 2005;80(3):910-916. [pmid: 16122453]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
201 Lin M-S, et al. Neurocognitive improvement after carotid artery stenting in patients with chronic internal carotid artery occlusion and cerebral ischemia. Stroke. 2011;42(10):2850-2854. [pmid: 21836094]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
202 Lindsay GM, et al. Assessment of changes in general health status using the short-form 36 questionnaire 1 year following coronary artery bypass grafting. European Journal of Cardio-Thoracic Surgery. 2000;18(5):557-564. [pmid: 11053817]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
203 Liu Y-H, et al. The effects of cardiopulmonary bypass on the number of cerebral microemboli and the incidence of cognitive dysfunction after coronary artery bypass graft surgery. Anesthesia & Analgesia. 2009;109(4):1013-1022. [pmid: 19762724]. POPULATION MEAN AGE <65
204 Lloyd AJ, et al. Does carotid endarterectomy lead to a decline in cognitive function or health related quality of life?. Journal of Clinical & Experimental Neuropsychology: Official Journal of the International Neuropsychological Society. 2004;26(6):817-825. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
205 Lloyd CT, et al. Serum S-100 protein release and neuropsychologic outcome during coronary revascularization on the beating heart: a prospective randomized study. Journal of Thoracic & Cardiovascular Surgery. 2000;119(1):148-154. [pmid: 10612774]. POPULATION MEAN AGE <65
206 Lund C, et al. Comparison of cerebral embolization during off-pump and on-pump coronary artery bypass surgery. Annals of Thoracic Surgery. 2003;76(3):765-770. discussion 770. [pmid: 12963195]. POPULATION MEAN AGE <65
207 Lyketsos CG, et al. A population-based study of the association between coronary artery bypass graft surgery (CABG) and cognitive decline: the Cache County study. International Journal of Geriatric Psychiatry. 2006;21(6):509-518. [pmid: 16645936]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
208 Maekawa K, et al. Impaired cognition preceding cardiac surgery is related to cerebral ischemic lesions. Journal of Anesthesia. 25(3):330-336. [pmid: 21448769]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
209 Mahanna EP, et al. Defining neuropsychological dysfunction after coronary artery bypass grafting. Annals of Thoracic Surgery. 1996;61(5):1342-1347. [pmid: 8633938]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
210 Maldonado JR, et al. Dexmedetomidine and the reduction of postoperative delirium after cardiac surgery. Psychosomatics. 2009;50(3):206-217. [pmid: 19567759]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
211 Malheiros SM, et al. Neurological outcome in coronary artery surgery with and without cardiopulmonary bypass. Acta Neurologica Scandinavica. 1995;92(3):256-260. [pmid: 7484082]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
212 Mariani MA, D'Alfonso A, Grandjean JG. Total arterial off-pump coronary surgery: time to change our habits?. Annals of Thoracic Surgery. 2004;78(5):1591-1597. [pmid: 15511438]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
213 Maron DJ, et al. Intensive Multifactorial Intervention for Stable Coronary Artery Disease. Optimal Medical Therapy in the COURAGE (Clinical Outcomes Utilizing Revascularization and Aggressive Drug Evaluation) Trial. J Am Coll Cardiol. 55(13):1348-1358. [pmid: 20338496]. POPULATION MEAN AGE <65
214 Martens S, et al. Conventional carbon dioxide application does not reduce cerebral or myocardial damage in open heart surgery. Annals of Thoracic Surgery. 2001;72(6):1940-1944. [pmid: 11789775]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
215 Mathew JP, et al. A Multicenter Risk Index for Atrial Fibrillation after Cardiac Surgery. Journal of the American Medical Association. 2004;291(14):1720-1729. [pmid: 15082699]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
216 Mathew JP, et al. Effects of extreme hemodilution during cardiac surgery on cognitive function in the elderly. Anesthesiology. 2007;107:577-584. [doi: 10.1097/01.anes.0000281896.07256.71]. [pmid: 17893453]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
217 Mathew JP, et al. Genetic variants in P-selectin and C-reactive protein influence susceptibility to cognitive decline after cardiac surgery. Journal of the American College of Cardiology. 2007;49(19):1934-1942. [pmid: 17498578]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
218 Mathisen L, et al. Changes in cardiac and cognitive function and self-reported outcomes at one year after coronary artery bypass grafting. Journal of Thoracic & Cardiovascular Surgery. 2010;140(1):122-128. [pmid: 20018306]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
219 Mattlar CE, et al. The proportion of patients with cognitive impairment after coronary artery bypass surgery: an 8-month follow-up study. Psychotherapy & Psychosomatics. 1991;55(2–4):145-150. [pmid: 1891561]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
220 McKhann GM, et al. Depression and cognitive decline after coronary artery bypass grafting. Lancet. 1997;349(9061):1282-1284. [pmid: 9142062]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
221 McKhann GM, et al. Cognitive outcome after coronary artery bypass: a one-year prospective study. Annals of Thoracic Surgery. 1997;63(2):510-515. [pmid: 9033329]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
222 McKhann GM, et al. Subjective memory symptoms in surgical and nonsurgical coronary artery patients: 6-year follow-up. Annals of Thoracic Surgery. 2009;87(1):27-34. [pmid: 19101263]. POPULATION MEAN AGE <65
223 McLean RF, et al. Cardiopulmonary bypass, temperature, and central nervous system dysfunction. Circulation. 1994;90(5 Pt 2):II250-II255. [pmid: 7955261]. POPULATION MEAN AGE <65
224 Meyer JS, et al. Effects of medical and surgical treatment on cerebral perfusion and cognition in patients with chronic cerebral ischemia. Surgical neurology. 1990;34:301-308. [pmid: 2218849]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
225 Mielke MM, et al. Vascular factors predict rate of progression in Alzheimer disease. Neurology. 2007;69(19):1850-1858. [pmid: 17984453]. NOT TREATED WITH CV PROCEDURE OF INTEREST
226 Millar K, Asbury AJ, Murray GD. Pre-existing cognitive impairment as a factor influencing outcome after cardiac surgery. British Journal of Anaesthesia. 2001;86(1):63-67. [pmid: 11575412]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
227 Mirow N, et al. Diffusion-weighted magnetic resonance imaging for the detection of ischemic brain lesions in coronary artery bypass graft surgery: relation to extracorporeal circulation and heparinization. Journal of Cardiovascular Surgery. 2011;52(1):117-126. [pmid: 21224820]. NO POST-PROCEDURE MEASURE OF COGNITION
228 Mitchell SJ, et al. Cerebral protection by lidocaine during cardiac operations: a follow-up study. Annals of Thoracic Surgery. 2009;87(3):820-825. [pmid: 19231397]. POPULATION MEAN AGE <65
229 Miyanaga S, et al. Impact of pulmonary vein isolation on the autonomic modulation in patients with paroxysmal atrial fibrillation and prolonged sinus pauses. Europace : European pacing, arrhythmias, and cardiac electrophysiology : journal of the working groups on cardiac pacing, arrhythmias, and cardiac cellular electrophysiology of the European Society of Cardiology. 2009;11:576-581. [doi: 10.1093/europace/eup082]. NO POST-PROCEDURE MEASURE OF COGNITION
230 Mlekusch W, et al. Improvement of neurocognitive function after protected carotid artery stenting. Catheterization & Cardiovascular Interventions. 2008;71(1):114-119. [pmid: 18098213]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
231 Mocco J, et al. Galbraith Award: evaluation of risk factors associated with neurocognitive changes after carotid endarterectomy. Clinical Neurosurgery. 2006;53:301-306. [pmid: 17380766]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
232 Mongero LB, et al. Cardiac surgical patients exposed to heparin-bonded circuits develop less postoperative cerebral dysfunction than patients exposed to non-heparin-bonded circuits. Perfusion. 2001;16(2):107-111. [pmid: 11334193]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
233 Mononen H, Lepojarvi M, Kallanranta T. Early neuropsychological outcome after carotid endarterectomy. European Neurology. 1990;30(6):328-333. [pmid: 2289509]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
234 Mora CT, et al. The effect of temperature management during cardiopulmonary bypass on neurologic and neuropsychologic outcomes in patients undergoing coronary revascularization. Journal of Thoracic & Cardiovascular Surgery. 1996;112(2):514-522. [pmid: 8751521]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
235 Moraca R, et al. Impaired baseline regional cerebral perfusion in patients referred for coronary artery bypass. Journal of Thoracic & Cardiovascular Surgery. 2006;131(3):540-546. [pmid: 16515903]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
236 Moran SM, et al. Prediction of survival by the Clifton Assessment Procedures for the Elderly (CAPE). British Journal of Clinical Psychology. 1990;29(Pt 2):225-226. [pmid: 2364201]. NOT TREATED WITH CV PROCEDURE OF INTEREST
237 Mortensen OS, et al. Health related quality of life after conservative or invasive treatment of inducible postinfarction ischaemia. DANAMI study group. Heart. 2000;84(5):535-540. [pmid: 11040017]. POPULATION MEAN AGE <65
238 Moser DJ, et al. Neuropsychological performance is associated with vascular function in patients with atherosclerotic vascular disease. Arteriosclerosis, Thrombosis, and Vascular Biology. 2007;27(1):141-146. NOT TREATED WITH CV PROCEDURE OF INTEREST
239 Motallebzadeh R, et al. Neurocognitive function and cerebral emboli: randomized study of on-pump versus off-pump coronary artery bypass surgery. Annals of Thoracic Surgery. 2007;83(2):475-482. [pmid: 17257972]. POPULATION MEAN AGE <65
240 Mracek J, et al. The impact of general versus local anesthesia on early subclinical cognitive function following carotid endarterectomy evaluated using P3 event-related potentials. Acta Neurochirurgica. 2012;154(3):433-438. [pmid: 22245975]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
241 Mullges W, et al. Cognitive performance after coronary artery bypass grafting: a follow-up study. Neurology. 2002;59(5):741-743. [pmid: 12221167]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
242 Mullges W, et al. Early natural course of transient encephalopathy after coronary artery bypass grafting. Critical Care Medicine. 2000;28(6):1808-1811. [pmid: 10890624]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
243 Mullges W, et al. Reduced rate of microembolism by optimized aortic cannula position does not influence early postoperative cognitive performance in CABG patients. Cerebrovascular Diseases. 2003;15(3):192-198. [pmid: 12646779]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
244 Murata K, et al. Cognitive alteration after carotid revascularization is correlated with cortical GABA B-ergic modulations. Neuroscience Letters. 500(3):151-156. [pmid: 21672610]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
245 Murkin JM, et al. A randomized study of the influence of perfusion technique and pH management strategy in 316 patients undergoing coronary artery bypass surgery. II. Neurologic and cognitive outcomes. Journal of Thoracic & Cardiovascular Surgery. 1995;110(2):349-362. [pmid: 7637352]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
246 Musumeci F, et al. Prospective randomized trial of single clamp technique versus intermittent ischaemic arrest: myocardial and neurological outcome. European journal of cardio-thoracic surgery : official journal of the European Association for Cardio-thoracic Surgery. 1998;13:702-709. [pmid: 9686803]. POPULATION MEAN AGE <65
247 Mutch WAC, et al. Dementia and depression with ischemic heart disease: a population-based longitudinal study comparing interventional approaches to medical management. PLoS ONE [Electronic Resource]. 2011;6(2):e17457. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
248 Nadareishvili ZG, et al. Is cerebral microembolism in mechanical prosthetic heart valves clinically relevant?. Journal of Neuroimaging. 2002;12(4):310-315. [pmid: 12380477]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
249 Nathan HJ, et al. The management of temperature during cardiopulmonary bypass: Effect on neuropsychological outcome. Journal of Cardiac Surgery. 1995;10(4 SUPPL.):481-487. [pmid: 7579846]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
250 Neville MJ, et al. Similar neurobehavioral outcome after valve or coronary artery operations despite differing carotid embolic counts. Journal of Thoracic & Cardiovascular Surgery. 2001;121(1):125-136. [pmid: 11135169]. POPULATION MEAN AGE <65
251 Newman MF, et al. Effect of aging on cerebral autoregulation during cardiopulmonary bypass. Association with postoperative cognitive dysfunction. Circulation. 1994;90(5 Pt 2):II243-II249. [pmid: 7955260]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
252 Newman MF, et al. Longitudinal assessment of neurocognitive function after coronary-artery bypass surgery.[Erratum appears in N Engl J Med 2001 Jun 14;344(24):1876]. New England Journal of Medicine. 2001;344(6):395-402. [pmid: 11172175]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
253 Nilsson J, et al. A randomized study of coronary artery bypass surgery performed with the Resting Heart™ System utilizing a low vs a standard dosage of heparin. Interact Cardiovasc Thorac Surg. 2012;15(5):834-839. [pmid: 22914806]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
254 Novitzky D, et al. A study design to assess the safety and efficacy of on-pump versus off-pump coronary bypass grafting: the ROOBY trial. Clinical Trials. 2007;4(1):81-91. [pmid: 17327248]. NO POST-PROCEDURE MEASURE OF COGNITION
255 Nussmeier NA, et al. Predictive value of the National Institutes of Health Stroke Scale and the Mini-Mental State Examination for neurologic outcome after coronary artery bypass graft surgery. Journal of Thoracic & Cardiovascular Surgery. 2010;139(4):901-912. [pmid: 19744674]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
256 Oden KE, Kevorkian CG, Levy KJK. Rehabilitation of the post-cardiac surgery stroke patient: analysis of cognitive and functional assessment. Archives of Physical Medicine & Rehabilitation. 1998;79(1):67-71. [pmid: 9440421]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
257 Ogasawara K, et al. Postoperative cerebral hyperperfusion associated with impaired cognitive function in patients undergoing carotid endarterectomy. Journal of Neurosurgery. 2005;102(1):38-44. [pmid: 15658094]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
258 Oh YJ, et al. Diabetes mellitus does not affect jugular bulb oxygen saturation in patients undergoing off-pump coronary artery bypass graft surgery. Circulation Journal. 2008;72(8):1259-1264. [pmid: 18654010]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
259 Okita Y, et al. Prospective comparative study of brain protection in total aortic arch replacement: Deep hypothermic circulatory arrest with retrograde cerebral perfusion or selective antegrade cerebral perfusion. Annals of Thoracic Surgery. 2001;72(1):72-79. [pmid: 11465234]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
260 Okonkwo OC, et al. Longitudinal trajectories of cognitive decline among older adults with cardiovascular disease. Cerebrovascular Diseases. 2010;30(4):362-373. [pmid: 20693791]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
261 Oprisiu-Fournier R, et al. AT1 receptor blockers for cognition decline after cardiac surgery? [13]. Stroke. 2006;37(11):2666. [pmid: 16973924]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
262 Orne RMLE, Balacumaraswami L. Benefits of off-pump coronary artery surgery?. Anaesthesia. 2003;58(5):481-482. [pmid: 12694007]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
263 Ortega G, Alvarez B, Quintana M, et al. Cognitive improvement in patients with severe carotid artery stenosis after transcervical stenting with protective flow reversal. Cerebrovasc Dis. 2013;35(2):124-130. [pmid: 23406878]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
264 Pacini D, et al. Cerebral functions and metabolism after antegrade selective cerebral perfusion in aortic arch surgery. European Journal of Cardio-Thoracic Surgery. 2010;37(6):1322-1331. [pmid: 20138537]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
265 Palombo D, et al. Subtle cerebral damage after shunting vs non shunting during carotid endarterectomy. European Journal of Vascular & Endovascular Surgery. 2007;34(5):546-551. [pmid: 17681825]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
266 Palotas A, et al. Coronary artery bypass surgery provokes Alzheimer's disease-like changes in the cerebrospinal fluid. Journal of Alzheimer's Disease. 2010;21(4):1153-1164. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
267 Panagopoulou E, Montgomery A, Benos A. Quality of life after coronary artery bypass grafting: evaluating the influence of preoperative physical and psychosocial functioning. Journal of Psychosomatic Research. 2006;60(6):639-644. [pmid: 16731241]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
268 Panday GFV, et al. Minimal extracorporeal circulation and off-pump compared to conventional cardiopulmonary bypass in coronary surgery. Interactive Cardiovascular & Thoracic Surgery. 2009;9(5):832-836. [pmid: 19671581]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
269 Pandit JJ, Pigott D. Cognitive dysfunction after cardiac surgery: Strategies for prevention. British Journal of Cardiology. 2001;8(11):613-616. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
270 Patel D, et al. Long-term functional and neurocognitive recovery in patients who had an acute cerebrovascular event secondary to catheter ablation for atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2010;21(4):412-417. [pmid: 19925610]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
271 Patel RL, et al. Alpha-stat acid-base regulation during cardiopulmonary bypass improves neuropsychologic outcome in patients undergoing coronary artery bypass grafting. Journal of Thoracic & Cardiovascular Surgery. 1996;111(6):1267-1279. [pmid: 8642829]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
272 Patel RL, et al. Hyperperfusion and cerebral dysfunction. Effect of differing acid-base management during cardiopulmonary bypass. European Journal of Cardio-Thoracic Surgery. 1993;7(9):457-463. discussion 464. [pmid: 8217224]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
273 Pearson S, Maddern G, Fitridge R. Cognitive performance in patients after carotid endarterectomy. Journal of Vascular Surgery. 2003;38(6):1248-1252. discussion 1252–3. [pmid: 14681622]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
274 Petrovitch H, et al. Influence of myocardial infarction, coronary artery bypass surgery, and stroke on cognitive impairment in late life. American Journal of Cardiology. 1998;81(8):1017-1021. [pmid: 9576163]. NOT TREATED WITH CV PROCEDURE OF INTEREST
275 Petrucci RJ. Finding our way from the heart to the head. Journal of Thoracic and Cardiovascular Surgery. 2003;126(4):944-946. [pmid: 14566229]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
276 Pettigrew LC, et al. Low mini-mental status predicts mortality in asymptomatic carotid arterial stenosis. Asymptomatic Carotid Atherosclerosis Study investigators. Neurology. 2000;55(1):30-34. [pmid: 10891899]. NO POST-PROCEDURE MEASURE OF COGNITION
277 Phillips Bute B, et al. Female gender is associated with impaired quality of life 1 year after coronary artery bypass surgery. Psychosomatic Medicine. 2003;65(6):944-951. [pmid: 14645771]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
278 Pirraglia PA, et al. The efficacy and safety of a pharmacologic protocol for maintaining coronary artery bypass patients at a higher mean arterial pressure during cardiopulmonary bypass. The Journal of extra-corporeal technology. 1998;30:64-72. [pmid: 10182115]. NO POST-PROCEDURE MEASURE OF COGNITION
279 Potter GG, et al. Age effects of coronary artery bypass graft on cognitive status change among elderly male twins. Neurology. 2004;63(12):2245-2249. [pmid: 15623681]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
280 Prapas SN, et al. Female risk using OPCAB, pi-circuit, and aorta no-touch coronary revascularization. The heart surgery forum. 2009;12:E344-E348. [doi: 10.1532/HSF98.20091124]. [pmid: 20037100]. NO POST-PROCEDURE MEASURE OF COGNITION
281 Prapas SN, et al. Aorta no-touch off-pump coronary artery revascularization in octogenarians: 5 Years' experience. Heart Surgery Forum. 2009;12(6):E349-E353. [pmid: 20037101]. NO POST-PROCEDURE MEASURE OF COGNITION
282 Proust F, et al. Quality of life and brain damage after microsurgical clip occlusion or endovascular coil embolization for ruptured anterior communicating artery aneurysms: Neuropsychological assessment - Clinical article. Journal of Neurosurgery. 2009;110(1):19-29. [pmid: 18928356]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
283 Puskas F, et al. Intraoperative hyperglycemia and cognitive decline after CABG. Annals of Thoracic Surgery. 2007;84(5):1467-1473. [pmid: 17954047]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
284 Puskas JD, et al. Neurocognitive and neuroanatomic changes after off-pump versus on-pump coronary artery bypass grafting: long-term follow-up of a randomized trial. Journal of Thoracic & Cardiovascular Surgery. 2011;141(5):1116-1127. [pmid: 21334013]. POPULATION MEAN AGE <65
285 Raabe RD, Burr RB, Short R. One-year Cognitive Outcomes Associated with Carotid Artery Stent Placement. Journal of Vascular and Interventional Radiology. 21(7):983-988. [pmid: 20537561]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
286 Rabee HM, et al. Neurobehavioral effects of carotid endarterectomy. Saudi Medical Journal. 2001;22(5):433-437. [pmid: 11376387]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
287 Ramlawi B, et al. Serologic markers of brain injury and cognitive function after cardiopulmonary bypass. Annals of Surgery. 2006;244(4):593-601. [pmid: 16998368]. NO POST-PROCEDURE MEASURE OF COGNITION
288 Rankin KP, et al. Presurgical cognitive deficits in patients receiving coronary artery bypass graft surgery. Journal of the International Neuropsychological Society. 2003;9(6):913-924. [pmid: 14632250]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
289 Rasmussen LS, et al. Do blood levels of neuron-specific enolase and S-100 protein reflect cognitive dysfunction after coronary artery bypass?. Acta Anaesthesiologica Scandinavica. 1999;43(5):495-500. [pmid: 10341995]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
290 Rasmussen LS, et al. Subtle brain damage cannot be detected by measuring neuron-specific enolase and S-100beta protein after carotid endarterectomy. Journal of Cardiothoracic & Vascular Anesthesia. 2000;14(2):166-170. [pmid: 10794336]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
291 Raymond PD, et al. Assessment of statistical change criteria used to define significant change in neuropsychological test performance following cardiac surgery. European Journal of Cardio-Thoracic Surgery. 2006;29(1):82-88. [pmid: 16337395]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
292 Reents W, et al. Reduction of cerebral microemboli by positioning the aortic cannula in the descending aorta. Kardiotechnik. 2002;11:41-44. FULL TEXT UNAVAILABLE
293 Regragui I, et al. The effects of cardiopulmonary bypass temperature on neuropsychologic outcome after coronary artery operations: a prospective randomized trial. Journal of Thoracic & Cardiovascular Surgery. 1996;112(4):1036-1045. [pmid: 8873731]. POPULATION MEAN AGE <65
294 Reich DL, et al. Using jugular bulb oxyhemoglobin saturation to guide onset of deep hypothermic circulatory arrest does not affect post-operative neuropsychological function. European Journal of Cardio-Thoracic Surgery. 2004;25(3):401-406. [pmid: 15019667]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
295 Reis HJ, et al. Different inflammatory biomarker patterns in the cerebro-spinal fluid following heart surgery and major non-cardiac operations. Current Drug Metabolism. 2007;8(6):639-642. [pmid: 17691923]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
296 Restrepo L, et al. Diffusion- and perfusion-weighted magnetic resonance imaging of the brain before and after coronary artery bypass grafting surgery. Stroke. 2002;33(12):2909-2915. [pmid: 12468790]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
297 Rimington H, Weinman J, Chambers JB. Predicting outcome after valve replacement. Heart. 2010;96(2):118-123. [pmid: 19502242]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
298 Roach GW, et al. Adverse cerebral outcomes after coronary bypass surgery. Multicenter Study of Perioperative Ischemia Research Group and the Ischemia Research and Education Foundation Investigators. New England Journal of Medicine. 1996;335(25):1857-1863. [pmid: 8948560]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
299 Roberts RO, et al. Coronary heart disease is associated with non-amnestic mild cognitive impairment. Neurobiology of Aging. 2010;31(11):1894-1902. [pmid: 19091445]. NOT TREATED WITH CV PROCEDURE OF INTEREST
300 Robson MJ, et al. Cognition after coronary artery surgery is not related to postoperative jugular bulb oxyhemoglobin desaturation. Anesthesia & Analgesia. 2000;91(6):1317-1326. [pmid: 11093972]. POPULATION MEAN AGE <65
301 Rodes-Cabau J, et al. Cerebral embolism following transcatheter aortic valve implantation: comparison of transfemoral and transapical approaches. Journal of the American College of Cardiology. 2011;57(1):18-28. [pmid: 21185496]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
302 Rodig G, et al. Evaluation of self-reported failures in cognitive function after cardiac and noncardiac surgery. Anaesthesia. 1999;54(9):826-830. [pmid: 10460551]. FULL TEXT UNAVAILABLE; NOT IN ENGLISH
303 Rodig G, Taeger K. Memory function in the early postoperative period after cardiac surgery - Impact of the anaesthetic procedure and comparison with memory function after vascular surgery. Anasthesiologie und Intensivmedizin. 2002;43:431-455. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
304 Rodriguez RA, et al. Cerebral emboli detected by transcranial Doppler during cardiopulmonary bypass are not correlated with postoperative cognitive deficits. Stroke. 2010;41(10):2229-2235. [pmid: 20724717]. POPULATION MEAN AGE <65
305 Rollman BL, Belnap BH. The Bypassing the Blues trial: collaborative care for post-CABG depression and implications for future research. Cleveland Clinic Journal of Medicine. Suppl 1. 2011;78:S4-S12. [pmid: 21972329]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
306 Roman PEF, Grigore AM. Pro: Hypothermic cardiopulmonary bypass should be used routinely. J Cardiothorac Vasc Anesth. 26(5):945-948. [pmid: 22790158]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
307 Ropacki SA, et al. The influence of cognitive reserve on neuropsychological functioning following coronary artery bypass grafting (CABG). Archives of Clinical Neuropsychology. 2007;22(1):73-85. [pmid: 17161581]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
308 Rosendahl J, et al. Bypass surgery with psychological and spiritual support (the By: pass study): study design and research methods. American Heart Journal. 2009;158(1):8-14.e1. [pmid: 19540386]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
309 Rosengart TK, et al. Neurocognitive functioning in patients undergoing coronary artery bypass graft surgery or percutaneous coronary intervention: evidence of impairment before intervention compared with normal controls. Annals of Thoracic Surgery. 2005;80(4):1327-1334. discussion 1334–5. [pmid: 16181864]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
310 Rothenhausler H-B. The effects of cardiac surgical procedures on health - related quality of life, cognitive performance, and emotional status outcomes: a prospective 6 - month follow - up study. Psychiatria Danubina. 2010;22(1):135-136. [pmid: 20305611]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
311 Rothenhausler H-B, et al. Psychiatric and psychosocial outcome of cardiac surgery with cardiopulmonary bypass: a prospective 12-month follow-up study. General Hospital Psychiatry. 2005;27(1):18-28. [pmid: 15694215]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
312 Royse AG, et al. Reduced neuropsychological dysfunction using epiaortic echocardiography and the exclusive Y graft. Annals of Thoracic Surgery. 2000;69(5):1431-1438. [pmid: 10881818]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
313 Royse C, et al. Prospective randomized trial of high thoracic epidural analgesia for coronary artery bypass surgery. Annals of Thoracic Surgery. 2003;75(1):93-100. [pmid: 12537199]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
314 Royse CF, et al. The influence of propofol or desflurane on postoperative cognitive dysfunction in patients undergoing coronary artery bypass surgery. Anaesthesia. 2011;66(6):455-464. [pmid: 21501129]. POPULATION MEAN AGE <65
315 Rubens FD, et al. The cardiotomy trial: a randomized, double-blind study to assess the effect of processing of shed blood during cardiopulmonary bypass on transfusion and neurocognitive function. Circulation. 2007;116(11 Suppl):I89-I97. [pmid: 17846332]. POPULATION MEAN AGE <65
316 Rudolph JL, et al. Independent Vascular and Cognitive Risk Factors for Postoperative Delirium. American Journal of Medicine. 2007;120(9):807-813. [pmid: 17765051]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
317 Rushford N, et al. Recall of information received in hospital by female cardiac patients. European Journal of Cardiovascular Prevention & Rehabilitation. 2007;14(3):463-469. [pmid: 17568250]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
318 Saczynski JS, et al. Cognitive trajectories after postoperative delirium. New England Journal of Medicine. 2012;367(1):30-39. [pmid: 22762316]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
319 Sader MA, et al. Neuropsychological and psychiatric outcomes following coronary surgery or angioplasty: A comparative study. Heart Lung and Circulation. 2002;11(2):95-101. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
320 Sahu B, et al. Neurocognitive function in patients undergoing coronary artery bypass graft surgery with cardiopulmonary bypass: the effect of two different rewarming strategies. Journal of Cardiothoracic & Vascular Anesthesia. 2009;23(1):14-21. [pmid: 18834816]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
321 Sakurai M, et al. Cognitive dysfunction following cardiovascular surgery. Japanese Journal of Thoracic and Cardiovascular Surgery. 2005;53(5):251-254. [pmid: 15952316]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
322 Saleh AA, et al. Effect of temperature during cardiopulmonary bypass on neurocognitive function in open heart surgery. Egyptian Journal of Anaesthesia. 2005;21(4):317-321. FULL TEXT UNAVAILABLE
323 Salenius JP, et al. Late results of surgical and nonoperative treatment of carotid stenosis. Eighty-four patients documented by angiography in 1974–1976. Journal of Cardiovascular Surgery. 1990;31(2):156-161. [pmid: 2341470]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
324 Samuels MA. Can cognition survive heart surgery?. Circulation. 2006;113(24):2784-2786. [pmid: 16785349]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
325 Sandau KE, et al. Health-related quality of life and subjective neurocognitive function three months after coronary artery bypass graft surgery. Heart & Lung. 2008;37(3):161-172. [pmid: 18482627]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
326 Sasoh M, et al. Effects of EC-IC bypass surgery on cognitive impairment in patients with hemodynamic cerebral ischemia. Surgical Neurology. 2003;59(6):455-460. [pmid: 12826338]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
327 Schmitz C, et al. Off-Pump versus on-pump coronary artery bypass: can OPCAB reduce neurologic injury?. Heart Surgery Forum. 2003;6(3):127-130. [pmid: 12821423]. POPULATION MEAN AGE <65
328 Schmitz C, et al. Can particulate extraction from the ascending aorta reduce neurologic injury in cardiac surgery?. Journal of Thoracic and Cardiovascular Surgery. 2003;126(6):1829-1838. [pmid: 14688694]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
329 Schoen J, et al. The association between gender, cognitive function, markers of inflammation and preoperative cerebral oxygen saturation in a cohort of preoperative cardiac surgery patients. Applied Cardiopulmonary Pathophysiology. 15(2):62-70. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
330 Schoen J, et al. Preoperative regional cerebral oxygen saturation is a predictor of postoperative delirium in on-pump cardiac surgery patients: A prospective observational trial. Critical Care. 15(5). NO POST-PROCEDURE MEASURE OF COGNITION
331 Scott DA, et al. Centrifugal versus roller head pumps for cardiopulmonary bypass: effect on early neuropsychologic outcomes after coronary artery surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2002;16(6):715-722. [pmid: 12486652]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
332 Sebregts EH, et al. Psychological effects of a short behavior modification program in patients with acute myocardial infarction or coronary artery bypass grafting. A randomized controlled trial. Journal of psychosomatic research. 2005;58:417-424. [doi: 10.1016/j.jpsychores.2004.02.021]. [pmid: 16026656]. NO POST-PROCEDURE MEASURE OF COGNITION
333 Sellman M, et al. A randomized study of neuropsychological function in patients undergoing coronary bypass surgery. Thoracic & Cardiovascular Surgeon. 1993;41(6):349-354. [pmid: 8128463]. POPULATION MEAN AGE <65
334 Sellman M, et al. Early neurological and electroencephalographic changes after coronary artery surgery in low-risk patients younger than 70 years. Thoracic & Cardiovascular Surgeon. 1991;39(2):76-80. [pmid: 1877056]. NO POST-PROCEDURE MEASURE OF COGNITION
335 Selnes OA. Comparison of cerebral embolization during off-pump and on-pump coronary artery bypass surgery: Invited commentary. Annals of Thoracic Surgery. 2003;76(3):770. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
336 Selnes OA, et al. Cognition 6 years after surgical or medical therapy for coronary artery disease. Annals of Neurology. 2008;63(5):581-590. [pmid: 18481292]. POPULATION MEAN AGE <65
337 Selnes OA, et al. Do management strategies for coronary artery disease influence 6-year cognitive outcomes?. Annals of Thoracic Surgery. 2009;88(2):445-454. [pmid: 19632391]. POPULATION MEAN AGE <65
338 Selnes OA, et al. Cognitive changes with coronary artery disease: a prospective study of coronary artery bypass graft patients and nonsurgical controls. Annals of Thoracic Surgery. 2003;75(5):1377-1384. discussion 1384–6. [pmid: 12735550]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
339 Sendelbach S, et al. Early neurocognitive function of patients after off-pump coronary artery bypass surgery. Heart & Lung. 2005;34(6):367-374. [pmid: 16324955]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
340 Sendelbach S, et al. Correlates of neurocognitive function of patients after off-pump coronary artery bypass surgery. American Journal of Critical Care. 2006;15(3):290-298. [pmid: 16632771]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
341 Shaaban-Ali M, et al. Changes in serum S100beta protein and Mini-Mental State Examination after cold (28 degrees C) and warm (34 degrees C) cardiopulmonary bypass using different blood gas strategies (alpha-stat and pH-stat). Acta Anaesthesiologica Scandinavica. 2002;46(1):10-16. [pmid: 11903066]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
342 Shelley M, Pakenham KI, Frazer I. Cortisol changes interact with the effects of a cognitive behavioural psychological preparation for surgery on 12-month outcomes for surgical heart patients. Psychology & health. 2009;24:1139-1152. [doi: 10.1080/08870440802126704]. [pmid: 20204984]. POPULATION MEAN AGE <65
343 Shroyer AL, et al. On-pump versus off-pump coronary-artery bypass surgery. New England Journal of Medicine. 2009;361(19):1827-1837. [pmid: 19890125]. POPULATION MEAN AGE <65
344 Shuhaiber JH, et al. Randomized prospective trial for blood transfusion during adult cardiopulmonary bypass surgery [8] (multiple letters). Journal of Thoracic and Cardiovascular Surgery. 2005;129(5):1200-1202. [pmid: 15867816]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
345 Siepe M, et al. Increased systemic perfusion pressure during cardiopulmonary bypass is associated with less early postoperative cognitive dysfunction and delirium. European Journal of Cardio-Thoracic Surgery. 2011;40(1):200-207. [pmid: 21168339]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
346 Silbert BS, et al. Preexisting cognitive impairment in patients scheduled for elective coronary artery bypass graft surgery. Anesthesia & Analgesia. 2007;104(5):1023-1028. tables of contents. [pmid: 17456647]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
347 Sirkka A, et al. Quality of life and cognitive performance after carotid endarterectomy during long-term follow-up. Acta Neurologica Scandinavica. 1992;85(1):58-62. [pmid: 1546536]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
348 Skrabal CA, et al. Effects of poly-2-methoxyethylacrylate (PMEA)-coating on CPB circuits. Scandinavian Cardiovascular Journal. 2006;40(4):224-229. [pmid: 16914413]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
349 Slater JP, et al. Cerebral oxygen desaturation predicts cognitive decline and longer hospital stay after cardiac surgery. Annals of Thoracic Surgery. 2009;87(1):36-44. discussion 44–5. [pmid: 19101265]. POPULATION MEAN AGE <65
350 Sloan FA, et al. The effect of dementia on outcomes and process of care for Medicare beneficiaries admitted with acute myocardial infarction. Journal of the American Geriatrics Society. 2004;52(2):173-181. [pmid: 14728624]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
351 Smith MH, et al. Age and other risk factors for neuropsychologic decline in patients undergoing coronary artery bypass graft surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2000;14(4):428-432. [pmid: 10972610]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
352 Smolderen KG, et al. The association of cognitive and somatic depressive symptoms with depression recognition and outcomes after myocardial infarction. Circulation: Cardiovascular Quality and Outcomes. 2009;2(4):328-337. [pmid: 20031858]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
353 Sousa Uva M, et al. Early graft patency after off-pump and on-pump coronary bypass surgery: a prospective randomized study. European Heart Journal. 2010;31(20):2492-2499. [pmid: 20595221]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
354 Spezzaferri R, et al. Psychological disorders after coronary artery by-pass surgery: a one-year prospective study. Monaldi Archives for Chest Disease. 2009;72(4):200-205. [pmid: 20183958]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
355 Stables RH. Design of the 'Stent or Surgery' trial (SoS): a randomized controlled trial to compare coronary artery bypass grafting with percutaneous transluminal coronary angioplasty and primary stent implantation in patients with multi-vessel coronary artery disease. Seminars in Interventional Cardiology. 1999;4(4):201-207. [pmid: 10738353]. NO POST-PROCEDURE MEASURE OF COGNITION
356 Stanley TO, et al. The impact of postoperative atrial fibrillation on neurocognitive outcome after coronary artery bypass graft surgery. Anesthesia & Analgesia. 2002;94(2):290-295. table of contents. [pmid: 11812686]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
357 Strauss B, et al. Preoperative and late postoperative psychosocial state following coronary artery bypass surgery.[Erratum appears in Thorac Cardiovasc Surg 1992 Jun;40(3)167]. Thoracic & Cardiovascular Surgeon. 1992;40(2):59-64. [pmid: 1631873]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
358 Stroobant N, et al. Short-term and long-term neurocognitive outcome in on-pump versus off-pump CABG. European Journal of Cardio-Thoracic Surgery. 2002;22(4):559-564. [pmid: 12297172]. POPULATION MEAN AGE <65
359 Stroobant N, et al. Neuropsychological functioning 3–5 years after coronary artery bypass grafting: does the pump make a difference?. European Journal of Cardio-Thoracic Surgery. 2008;34(2):396-401. [pmid: 18524617]. POPULATION MEAN AGE <65
360 Stroobant N, et al. Relation between neurocognitive impairment, embolic load, and cerebrovascular reactivity following on- and off-pump coronary artery bypass grafting.[Erratum appears in Chest 2006 Jan;129(1)216]. Chest. 2005;127(6):1967-1976. [pmid: 15947309]. POPULATION MEAN AGE <65
361 Stroobant N, Vingerhoets G. Depression, anxiety, and neuropsychological performance in coronary artery bypass graft patients: a follow-up study. Psychosomatics. 2008;49(4):326-331. [pmid: 18621938]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
362 Stygall J, et al. Cognitive change 5 years after coronary artery bypass surgery. Health psychology : official journal of the Division of Health Psychology, American Psychological Association. 2003;22:579-586. [doi: 10.1037/0278-6133.22.6.579]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
363 Stygall J, et al. Effect on the brain of two techniques of myocardial protection. Asian Cardiovascular & Thoracic Annals. 2009;17(3):259-265. [pmid: 19643849]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
364 Sugiyama N, et al. The incidence and severity of cognitive decline after major noncardiac surgery: A comparison with that after cardiac surgery with cardiopulmonary bypass. Journal of Anesthesia. 2002;16(3):261-264. [pmid: 14517654]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
365 Suksompong S, et al. Neuropsychological alterations after coronary artery bypass graft surgery. Journal of the Medical Association of Thailand. Suppl 3. 2002;85:S910-S916. [pmid: 12452229]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
366 Svenmarker S, et al. Neurological and general outcome in low-risk coronary artery bypass patients using heparin coated circuits. European Journal of Cardio-Thoracic Surgery. 2001;19(1):47-53. [pmid: 11163560]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
367 Svenmarker S, et al. Clinical effects of the heparin coated surface in cardiopulmonary bypass. European Journal of Cardio-Thoracic Surgery. 1997;11(5):957-964. [pmid: 9196315]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
368 Svensson LG, et al. A prospective randomized study of neurocognitive function and S-100 protein after antegrade or retrograde brain perfusion with hypothermic arrest for aortic surgery. Journal of Thoracic and Cardiovascular Surgery. 2000;119(1):163-166. [pmid: 10612776]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
369 Svensson LG, Nadolny EM, Kimmel WA. Multimodal protocol influence on stroke and neurocognitive deficit prevention after ascending/arch aortic operations. Annals of Thoracic Surgery. 2002;74(6):2040-2046. [pmid: 12643393]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
370 Sweet JJ, et al. Absence of cognitive decline one year after coronary bypass surgery: comparison to nonsurgical and healthy controls. Annals of Thoracic Surgery. 2008;85(5):1571-1578. [pmid: 18442540]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
371 Taggart DP, et al. Serum S-100 protein concentration after cardiac surgery: a randomized trial of arterial line filtration. European journal of cardio-thoracic surgery : official journal of the European Association for Cardio-thoracic Surgery. 1997;11:645-649. [pmid: 9151031]. POPULATION MEAN AGE <65
372 Taggart DP, et al. Is cardiopulmonary bypass still the cause of cognitive dysfunction after cardiac operations?. Journal of Thoracic & Cardiovascular Surgery. 1999;118(3):414-420. discussion 420–1. [pmid: 10469952]. POPULATION MEAN AGE <65
373 Taggart DP, et al. Neuroprotection during cardiac surgery: a randomised trial of a platelet activating factor antagonist. Heart. 2003;89(8):897-900. [pmid: 12860868]. NO POST-PROCEDURE MEASURE OF COGNITION
374 Takaiwa A, et al. Changes in cognitive function during the 1-year period following endarterectomy and stenting of patients with high-grade carotid artery stenosis. Acta Neurochirurgica. 2009;151(12):1593-1600. [pmid: 19533017]. FULL TEXT UNAVAILABLE
375 Takaiwa A, et al. Cognitive function in patients with severe carotid stenosis - Evaluation of RBANS, WAIS-R and NART before treatment of carotid revascularization. Brain and Nerve. 2006;58(8):681-686. [pmid: 16986674]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
376 Tardiff BE, et al. Preliminary report of a genetic basis for cognitive decline after cardiac operations. The Neurologic Outcome Research Group of the Duke Heart Center. Annals of Thoracic Surgery. 1997;64(3):715-720. [pmid: 9307463]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
377 Thalmann M, et al. OPCAB: Reducing the Perioperative Risk Avoiding Extracorporeal Circulation in CABG Surgery. European Surgery - Acta Chirurgica Austriaca. 2003;35(6):327-329. NO POST-PROCEDURE MEASURE OF COGNITION
378 Thornton EW, et al. Quality of life outcomes after coronary artery bypass graft surgery: relationship to neuropsychologic deficit. Journal of Thoracic & Cardiovascular Surgery. 2005;130(4):1022-1027. [pmid: 16214514]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
379 Toner I, et al. Cerebral functional changes following cardiac surgery: Neuropsychological and EEG assessment. European Journal of Cardio-Thoracic Surgery. 1998;13(1):13-20. [pmid: 9504725]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
380 Tully PJ, et al. Neuropsychologic and quality-of-life outcomes after coronary artery bypass surgery with and without cardiopulmonary bypass: a prospective randomized trial. Journal of Cardiothoracic & Vascular Anesthesia. 2008;22(4):515-521. [pmid: 18662624]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
381 Tully PJ, et al. Neuropsychological function 5 years after cardiac surgery and the effect of psychological distress. Archives of Clinical Neuropsychology. 741. 2009;24:8-751. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
382 Turk AS, et al. Effect of carotid artery stenting on cognitive function in patients with carotid artery stenosis: preliminary results. Ajnr: American Journal of Neuroradiology. 2008;29(2):265-268. [pmid: 17989371]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
383 Uekermann J, et al. Neuropsychological deficits after mechanical aortic valve replacement. Journal of Heart Valve Disease. 2005;14(3):338-343. [pmid: 15974528]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
384 Uva MS, et al. Rationale, design and methodology for a prospective randomized study of graft patency in off-pump and on-pump multi-vessel coronary artery bypass surgery (PROMISS) using multidetector computed tomography. Trials. 2008;9. 44tn: isrctn58800729/isrctn. NO POST-PROCEDURE MEASURE OF COGNITION
385 Vaage J, Jensen U, Ericsson A. Neurologic injury in cardiac surgery: Aortic atherosclerosis emerges as the single most important risk factor. Scandinavian Cardiovascular Journal. 2000;34(6):550-557. [pmid: 11214006]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
386 van den Goor J, et al. Improvement of cognitive test performance in patients undergoing primary CABG and other CPB-assisted cardiac procedures. Perfusion. 2008;23(5):267-273. [pmid: 19346264]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
387 van Dijk D, et al. Beating heart versus conventional cardiopulmonary bypass: the octopus experience: a randomized comparison of 281 patients undergoing coronary artery bypass surgery with or without cardiopulmonary bypass. Seminars in Cardiothoracic & Vascular Anesthesia. 2006;10(2):167-170. [pmid: 16959744]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
388 Van Dijk D, et al. Cognitive outcome after off-pump and on-pump coronary artery bypass graft surgery: a randomized trial. JAMA. 2002;287(11):1405-1412. [pmid: 11903027]. POPULATION MEAN AGE <65
389 van Dijk D, et al. Association between early and three month cognitive outcome after off-pump and on-pump coronary bypass surgery. Heart. 2004;90(4):431-434. [pmid: 15020522]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
390 van Dijk D, et al. Cognitive outcomes five years after not undergoing coronary artery bypass graft surgery. Annals of Thoracic Surgery. 2008;85(1):60-64. [pmid: 18154780]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
391 van Dijk D, et al. Cognitive and cardiac outcomes 5 years after off-pump vs on-pump coronary artery bypass graft surgery. JAMA. 2007;297(7):701-708. [pmid: 17312289]. NO POST-PROCEDURE MEASURE OF COGNITION
392 van Mastrigt GAPG, et al. Health-related quality of life after fast-track treatment results from a randomized controlled clinical equivalence trial. Quality of Life Research. 2010;19(5):631-642. [pmid: 20340049]. POPULATION MEAN AGE <65
393 Vanninen R, et al. Subclinical cerebral complications after coronary artery bypass grafting: prospective analysis with magnetic resonance imaging, quantitative electroencephalography, and neuropsychological assessment. Archives of Neurology. 1998;55(5):618-627. [pmid: 9605718]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
394 Venn GE, Patel RL, Chambers DJ. Cardiopulmonary bypass: perioperative cerebral blood flow and postoperative cognitive deficit. Annals of Thoracic Surgery. 1995;59(5):1331-1335. [pmid: 7733763]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
395 Vingerhoets G, et al. Prospective evaluation of verbal memory performance after cardiopulmonary bypass surgery. Journal of Clinical & Experimental Neuropsychology: Official Journal of the International Neuropsychological Society. 1996;18(2):187-196. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
396 Vingerhoets G, Van Nooten G, Jannes C. Effect of asymptomatic carotid artery disease on cognitive outcome after cardiopulmonary bypass. Journal of the International Neuropsychological Society. 1996;2(3):236-239. [pmid: 9375189]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
397 Vingerhoets G, Van Nooten G, Jannes C. Neuropsychological impairment in candidates for cardiac surgery. Journal of the International Neuropsychological Society. 1997;3(5):480-484. [pmid: 9322408]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
398 Vingerhoets G, et al. Short-term and long-term neuropsychological consequences of cardiac surgery with extracorporeal circulation. European Journal of Cardio-Thoracic Surgery. 1997;11(3):424-431. [pmid: 9105803]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
399 Von Waldegg GH, Klement A. Cognitive impairments after bypass surgery. Kognitive beeinträchtigungen. 2009;106(42):693. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
400 Vuylsteke A, et al. Circulatory arrest versus cerebral perfusion during pulmonary endarterectomy surgery (PEACOG): A randomised controlled trial. The Lancet. 378(9800):1379-1387. POPULATION MEAN AGE <65
401 Wahlqvist M, Denvall V, Havelius U. No improvement of sustained attention after carotid endarterectomy as analysed by dark adaptometry. Cerebrovascular Diseases. 2003;16(1):91-94. [pmid: 12766369]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
402 Wahrborg P, et al. Neuropsychological outcome after percutaneous coronary intervention or coronary artery bypass grafting: results from the Stent or Surgery (SoS) Trial. Circulation. 2004;110(22):3411-3417. [pmid: 15557380]. POPULATION MEAN AGE <65
403 Wasser K, et al. Age-dependent effects of carotid endarterectomy or stenting on cognitive performance. Journal of Neurology. 259(11):2309-2318. [pmid: 22527231]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
404 Wasser K, et al. New brain lesions after carotid revascularization are not associated with cognitive performance. Journal of Vascular Surgery. 2011;53(1):61-70. [pmid: 20875716]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
405 Weber CF, et al. Impact of general versus local anesthesia on early postoperative cognitive dysfunction following carotid endarterectomy: GALA Study Subgroup Analysis. World Journal of Surgery. 2009;33(7):1526-1532. [pmid: 19424750]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
406 Weinstein CS, Woodard WJ, DeSilva RA. Late neurocognitive changes from neurological damage following coronary bypass surgery. Behavioral Medicine. 1998;24(3):131-137. [pmid: 9850807]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
407 Westaby S, et al. Is there a relationship between cognitive dysfunction and systemic inflammatory response after cardiopulmonary bypass?. Annals of Thoracic Surgery. 2001;71(2):667-672. [pmid: 11235725]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
408 Whitaker DC, Stygall J, Newman SP. Neuroprotection during cardiac surgery: Strategies to reduce cognitive decline. Perfusion. 2002;17(SUPPL.):69-75. [pmid: 12009088]. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
409 Wilson DA, et al. Post-carotid endarterectomy neurocognitive decline is associated with cerebral blood flow asymmetry on post-operative magnetic resonance perfusion brain scans. Neurological Research. 2008;30(3):302-306. [pmid: 17803842]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
410 Witt K, et al. Neuropsychological consequences of endarterectomy and endovascular angioplasty with stent placement for treatment of symptomatic carotid stenosis: a prospective randomised study. Journal of Neurology. 2007;254(11):1524-1532. [pmid: 17657403]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
411 Xu G, et al. Cognitive performance after carotid angioplasty and stenting with brain protection devices. Neurological Research. 2007;29(3):251-255. [pmid: 17178010]. NO POST-PROCEDURE MEASURE OF COGNITION
412 Yamashita T, et al. Combination of preoperative cerebral blood flow and 123I-iomazenil SPECT imaging predicts postoperative cognitive improvement in patients undergoing uncomplicated endarterectomy for unilateral carotid stenosis. Clinical Nuclear Medicine. 2012;37(2):128-133. [pmid: 22228333]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
413 Yates SL, Alston RP. Neurological, psychological and cognitive sequelae of cardiac surgery. Current Anaesthesia and Critical Care. 2000;11(4):187-193. NOT RCT/CCT OR PROSPECTIVE OBS. TRIAL
414 Zamvar V, et al. Assessment of neurocognitive impairment after off-pump and on-pump techniques for coronary artery bypass graft surgery: prospective randomised controlled trial. BMJ. 2002;325(7375):1268. [pmid: 12458242]. NO COGNITIVE OUTCOMES AT LEAST 3 MONTHS POST-PROCEDURE
415 Zhang Z, Ma P, Xu Y, et al. Preventive effect of gastrodin on cognitive decline after cardiac surgery with cardiopulmonary bypass: a double-blind, randomized controlled study. J Huazhong Univ Sci Technolog Med Sci. Feb. 2011;31(1):120-127. [pmid: 21336736]. POPULATION MEAN AGE <65
416 Zimpfer D, et al. Cognitive deficit after aortic valve replacement. Annals of Thoracic Surgery. 2002;74(2):407-412. discussion 412. [pmid: 12173821]. PROSPECTIVE OBS. COHORT W/O CV PROCEDURE OF INTEREST
417 Zimpfer D, et al. Long-term neurocognitive function after mechanical aortic valve replacement. Annals of Thoracic Surgery. 2006;81(1):29-33. [pmid: 16368330]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
418 Zimpfer D, et al. Neurocognitive deficit following coronary artery bypass grafting: a prospective study of surgical patients and nonsurgical controls. Annals of Thoracic Surgery. 2004;78(2):513-518. discussion 518–9. [pmid: 15276509]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)
419 Zimpfer D, et al. Neurocognitive deficit following aortic valve replacement with biological/mechanical prosthesis. European Journal of Cardio-Thoracic Surgery. 2003;23(4):544-551. [pmid: 12694774]. SAMPLE SIZE <10 (RCT); <50 (PROSPECTIVE OBS. COHORT)