# Abbreviations

ACS: American College of Surgery
AGS: American Geriatrics Society
AHRQ: Agency for Healthcare Research and Quality
AVR: aortic valve replacement
CABG: coronary artery bypass grafting
CAS: carotid artery stenting
CCT: controlled clinical trial
CEA: carotid endarterectomy
CENTRAL: Cochrane Central register of controlled trials
CV: cardiovascular
CVD: cardiovascular disease
KQ: key question
MCI: mild cognitive impairment
MLIS: Masters of Library and Information Science
MMSE: Mini Mental State Examination
MOCA: Montreal Cognitive Assessment
NR: not reported
PCI: percutaneous coronary intervention
RCT: randomized controlled trial
RevMan: Review Manager
RR: risk ratio
SD: standard deviation
SOE: strength of evidence
TAVR: transcatheter aortic valve replacement
TIA: transient ischemic attack