# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Rebecca F. Gottesman, MD, PhD
  Department of Neurology
  Johns Hopkins University School of Medicine
  Baltimore, MD
- David Knopman, MD
  Neurology, Mayo Clinic
  Rochester, MN
- Lenore Launer, PhD
  Neuroepidemiology National
  Institute of Health
  Bathesda, MD
- Ronald Lazar, PhD
  Neurology and Neurological
  Surgery Columbia University
  New York, NY
- Robin Varghese, MD, MS
  Assistant Professor of Surgery
  Department of Cardiothoracic Surgery
  Icahn School of Medicine, Mount Sinai Medical Center
  New York, NY
- Mary Woo, DNSc, RN, FAAN
  University of California, Los
  Angeles Los Angeles, CA
- Wei Zhou
  Vascular Surgery
  Stanford University and Palo Alto Veterans Affairs Health Care System
  Palo Alto, CA