# References

1 Selnes OA, Gottesman RF, Grega MA, et al. Cognitive and neurologic outcomes after coronary-artery bypass surgery. N Engl J Med. Jan. 19. 2012;366(3):250-257. [pmid: 22256807].
2 Murkin JM, Newman SP, Stump DA, et al. Statement of consensus on assessment of neurobehavioral outcomes after cardiac surgery. Ann Thorac Surg. May. 1995;59(5):1289-1295. [pmid: 7733754].
3 Cormack F, Shipolini A, Awad WI, et al. A meta-analysis of cognitive outcome following coronary artery bypass graft surgery. Neurosci Biobehav Rev. Oct. 2012;36(9):2118-2129. [pmid: 22732162].
4 Lombard FW, Mathew JP. Neurocognitive dysfunction following cardiac surgery. Semin Cardiothorac Vasc Anesth. Jun. 2010;14(2):102-110. [pmid: 20478950].
5 Dieleman J, Sauer AM, Klijn C, et al. Presence of coronary collaterals is associated with a decreased incidence of cognitive decline after coronary artery bypass surgery. Eur J Cardiothorac Surg. Jan. 2009;35(1):48-53. [pmid: 19027312].
6 Ho PM, Arciniegas DB, Grigsby J, et al. Predictors of cognitive decline following coronary artery bypass graft surgery. Ann Thorac Surg. Feb. 2004;77(2):597-603. discussion. [pmid: 14759444].
7 Kadoi Y, Kawauchi C, Ide M, et al. Preoperative depression is a risk factor for postoperative short-term and long-term cognitive dysfunction in patients with diabetes mellitus. J Anesth. Feb. 2011;25(1):10-17. [pmid: 21161290].
8 Alston RP. Brain damage and cardiopulmonary bypass: is there really any association?. Perfusion. Sep. Suppl 1. 2011;26:20-26. [pmid: 21933818].
9 Lunn S, Crawley F, Harrison MJ, et al. Impact of carotid endarterectomy upon cognitive functioning. A systematic review of the literature. Cerebrovasc Dis. Mar-Apr. 1999;9(2):74-81. [pmid: 9973649].
10 Irvine CD, Gardner FV, Davies AH, et al. Cognitive testing in patients undergoing carotid endarterectomy. Eur J Vasc Endovasc Surg. Mar. 1998;15(3):195-204. [pmid: 9587331].
11 Lacroix V, Hammer F, Astarci P, et al. Ischemic cerebral lesions after carotid surgery and carotid stenting. Eur J Vasc Endovasc Surg. Apr. 2007;33(4):430-435. [pmid: 17196846].
12 Crawley F, Stygall J, Lunn S, et al. Comparison of microembolism detected by transcranial Doppler and neuropsychological sequelae of carotid surgery and percutaneous transluminal angioplasty. Stroke. Jun. 2000;31(6):1329-1334. [pmid: 10835452].
13 De Rango P, Caso V, Leys D, et al. The role of carotid artery stenting and carotid endarterectomy in cognitive performance: a systematic review. Stroke. Nov. 2008;39(11):3116-3127. [pmid: 18723423].
14 Goldberg JB, Goodney PP, Kumbhani SR, et al. Brain injury after carotid revascularization: outcomes, mechanisms, and opportunities for improvement. Ann Vasc Surg. Feb. 2011;25(2):270-286. [pmid: 20926244].
15 Hynes BG, Rodes-Cabau J. Transcatheter aortic valve implantation and cerebrovascular events: the current state of the art. Ann N Y Acad Sci. Apr. 2012;1254:151-163. [pmid: 22548581].
16 Miller DC, Blackstone EH, Mack MJ, et al. Transcatheter (TAVR) versus surgical (AVR) aortic valve replacement: occurrence, hazard, risk factors, and consequences of neurologic events in the PARTNER trial. J Thorac Cardiovasc Surg. Apr. 2012;143(4):832-843 e13. [pmid: 22424519].
17 Grimm M, Zimpfer D, Czerny M, et al. Neurocognitive deficit following mitral valve surgery. Eur J Cardiothorac Surg. Mar. 2003;23(3):265-271. [pmid: 12614792].
18 Healey JS, Nair GM. Does catheter ablation for atrial fibrillation increase or reduce neurological insult?. Curr Opin Cardiol. Jan. 2012;27(1):36-40. [pmid: 22123602].
19 Bunch TJ, Crandall BG, Weiss JP, et al. Patients treated with catheter ablation for atrial fibrillation have long-term rates of death, stroke, and dementia similar to patients without atrial fibrillation. J Cardiovasc Electrophysiol. Aug. 2011;22(8):839-845. [pmid: 21410581].
20 Schwarz N, Kuniss M, Nedelmann M, et al. Neuropsychological decline after catheter ablation of atrial fibrillation. Heart Rhythm. Dec. 2010;7(12):1761-1767. [pmid: 20691284].
21 Higgins JP, Green S. Collaboration TC, editor. Cochrane Handbook for Systematic Reviews of Interventions, Version 5.1.0. 5.1.0 ed. 2011.
22 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
23 Schulz KF, Grimes DA. Allocation concealment in randomised trials: defending against deciphering. Lancet. Feb. 16. 2002;359(9306):614-618. [pmid: 11867132].
24 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. 2008. [pmid: 22479713].
25 RevMan RMcpV. Copenhagen:The Nordic Cochrance Centre of the Cochrane Collaboration. 2008.
26 Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. 2nd ed. ed. Hillsdale, NJ. Erlbaum. 1988.
27 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
28 Agency for Healthcare Research and Quality. Assessing the Quality and Applicability of Included Studies. Agency for Healthcare Research and Quality, ed Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2007.
29 Jensen BO, Rasmussen LS, Steinbruchel DA. Cognitive outcomes in elderly high-risk patients 1 year after off-pump versus on-pump coronary artery bypass grafting. A randomized trial. Eur J Cardiothorac Surg. Nov. 2008;34(5):1016-1021. [pmid: 18778948].
30 Nathan HJ, Rodriguez R, Wozny D, et al. Neuroprotective effect of mild hypothermia in patients undergoing coronary artery surgery with cardiopulmonary bypass: five-year follow-up of a randomized trial. J Thorac Cardiovasc Surg. May. 2007;133(5):1206-1211. [pmid: 17467430].
31 Selnes OA, Zeger SL. Coronary artery bypass grafting baseline cognitive assessment: essential not optional. Ann Thorac Surg. Feb. 2007;83(2):374-376. [pmid: 17257951].
32 Selnes OA, Grega MA, Borowicz LM Jr, et al. Cognitive outcomes three years after coronary artery bypass surgery: a comparison of on-pump coronary artery bypass graft surgery and nonsurgical controls. Ann Thorac Surg. Apr. 2005;79(4):1201-1209. [pmid: 15797050].
33 Lamy A, Devereaux PJ, Prabhakaran D, et al. Effects of off-pump and on-pump coronary-artery bypass grafting at 1 year. N Engl J Med. Mar. 28. 2013;368(13):1179-1188. [pmid: 23477676].
34 Knipp SC, Kahlert P, Jokisch D, et al. Cognitive function after transapical aortic valve implantation: a single-centre study with 3-month follow-up. Interact Cardiovasc Thorac Surg. Feb. 2013;16(2):116-122. [pmid: 23148084].
35 Jensen BO, Hughes P, Rasmussen LS, et al. Cognitive outcomes in elderly high-risk patients after off-pump versus conventional coronary artery bypass grafting: a randomized trial. Circulation. Jun. 20. 2006;113(24):2790-2795. [pmid: 16769915].
36 Lee JD, Lee SJ, Tsushima WT, et al. Benefits of off-pump bypass on neurologic and clinical morbidity: a prospective randomized trial. Ann Thorac Surg. Jul. 2003;76(1):18-25. discussion-6. [pmid: 12842506].
37 Lund C, Sundet K, Tennoe B, et al. Cerebral ischemic injury and cognitive impairment after off-pump and on-pump coronary artery bypass grafting surgery. Ann Thorac Surg. Dec. 2005;80(6):2126-2131. [pmid: 16305857].
38 McKhann GM, Selnes OA, Grega MA, et al. Subjective memory symptoms in surgical and nonsurgical coronary artery patients: 6-year follow-up. Ann Thorac Surg. Jan. 2009;87(1):27-34. [pmid: 19101263].
39 Vedin J, Nyman H, Ericsson A, et al. Cognitive function after on or off pump coronary artery bypass grafting. Eur J Cardiothorac Surg. Aug. 2006;30(2):305-310. [pmid: 16828295].
40 Anastasiadis K, Antonitsis P, Papakonstantinou C. When is the optimal time to perform neurocognitive assessment after coronary artery bypass surgery?. Ann Thorac Surg. Nov. 2011;92(5). 1933. author reply-4. [pmid: 22051305].
41 Boodhwani M, Rubens F, Wozny D, et al. Effects of sustained mild hypothermia on neurocognitive function after coronary artery bypass surgery: a randomized, double-blind study. J Thorac Cardiovasc Surg. Dec. 2007;134(6):1443-1450. discussion 51–2. [pmid: 18023662].
42 Nathan HJ, Wells GA, Munson JL, et al. Neuroprotective effect of mild hypothermia in patients undergoing coronary artery surgery with cardiopulmonary bypass: a randomized trial. Circulation. Sep. 18. Suppl 1. 2001;104(12):I85-I91. [pmid: 11568036].
43 Alex J, Laden G, Cale AR, et al. Pretreatment with hyperbaric oxygen and its effect on neuropsychometric dysfunction and systemic inflammatory response after cardiopulmonary bypass: a prospective randomized double-blind trial. J Thorac Cardiovasc Surg. Dec. 2005;130(6):1623-1630. [pmid: 16308008].
44 Silbert BS, Scott DA, Evered LA, et al. A comparison of the effect of high- and low-dose fentanyl on the incidence of postoperative cognitive dysfunction after coronary artery bypass surgery in the elderly. Anesthesiology. Jun. 2006;104(6):1137-1145. [pmid: 16732083].
45 Djaiani G, Katznelson R, Fedorko L, et al. Early benefit of preserved cognitive function is not sustained at one-year after cardiac surgery: a longitudinal follow-up of the randomized controlled trial. Can J Anaesth. May. 2012;59(5):449-455. [pmid: 22290354].
46 Gold JP, Charlson ME, Williams-Russo P, et al. Improvement of outcomes after coronary artery bypass. A randomized trial comparing intraoperative high versus low mean arterial pressure. J Thorac Cardiovasc Surg. Nov. 1995;110(5):1302-1311. discussion 11–4. [pmid: 7475182].
47 Flesch M, Knipp S, Kessler G, et al. ARTA: AT1-receptor blocker therapy in patients undergoing coronary artery bypass grafting. Clin Res Cardiol. Jan. 2009;98(1):33-43. [pmid: 18853093].
48 Andrew MJ, Baker RA, Bennetts J, et al. A comparison of neuropsychologic deficits after extracardiac and intracaradiac surgery. J Cardiothorac Vasc Anesth. Feb. 2001;15(1):9-14. [pmid: 11254832].
49 Altinbas A, van Zandvoort MJ, van den Berg E, et al. Cognition after carotid endarterectomy or stenting: a randomized comparison. Neurology. Sep. 13. 2011;77(11):1084-1090. [pmid: 21880992].
50 Baracchini C, Mazzalai F, Gruppo M, et al. Carotid endarterectomy protects elderly patients from cognitive decline: a prospective study. Surgery. Jan. 2012;151(1):99-106. [pmid: 21943640].
51 Fakin R, Zimpfer D, Sodeck GH, et al. Influence of temperature management on neurocognitive function in biological aortic valve replacement. A prospective randomized trial. J Cardiovasc Surg (Torino). Feb. 2012;53(1):107-112. [pmid: 22231536].
52 Anastasiadis K, Antonitsis P, Haidich AB, et al. Use of minimal extracorporeal circulation improves outcome after heart surgery; a systematic review and meta-analysis of randomized controlled trials. Int J Cardiol. Apr. 5. 2013;164(2):158-169. [pmid: 22325958].
53 Anastasiadis K. Comparison of Minimal Versus Conventional Extracorporeal Circulation in Coronary Surgery. www.clinicaltrials.cog: National Institutes of Health. 2014. NCT01603589.
54 Greer N, Anderson P, MacDonald R, Tacklind J, Rutks I, Wilt TJ. Delirium: Screening, Prevention, and Diagnosis - A Systematic Review of the Evidence. 2011.
55 United States Preventive Services Task Force. Screening for Dementia: Recommendations and Rationale. 2003. http://www.uspreventiveservicestaskforce.org/3rduspstf/dementia/dementrr.htm.
56 Chow WB, Rosenthal RA, Merkow RP, et al. Optimal preoperative assessment of the geriatric surgical patient: a best practices guideline from the American College of Surgeons National Surgical Quality Improvement Program and the American Geriatrics Society. J Am Coll Surg. Oct. 2012;215(4):453-466. [pmid: 22917646].