# Acknowledgments

The authors gratefully acknowledge Santiago Garcia, MD, for his early contributions to the design of this project.