# References

1 American Heart Association. Heart Disease and Stroke Statistics - 2006 Update. Dallas. American Heart Association. 2006.
2 Hamm CW, Goldmann BU, Heeschen C, et al. Emergency room triage of patients with acute chest pain by means of rapid testing for cardiac troponin T or troponin I. N Engl J Med. 1997;337(23):1648-53. [pmid: 9385123].
3 Patel MR, Peterson ED, Dai D, et al. Low diagnostic yield of elective coronary angiography. N Engl J Med. 362(10):886-95. [pmid: 20220183].
4 Lee TH, Goldman L. Evaluation of the patient with acute chest pain. N Engl J Med. 2000;342(16):1187-95. [pmid: 10770985].
5 Canadian Cardiovascular Society, American Academy of Family Physicians, American College of Cardiology, et al. 2007 focused update of the ACC/AHA 2004 guidelines for the management of patients with ST-elevation myocardial infarction: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. [erratum appears in J Am Coll Cardiol. 2008 Mar 4;51(9):977]. J Am Coll Cardiol. 2008;51(2):210-47. [pmid: 18191746].
6 Mirvis DM, Goldberger AL. Chapter 12 - Electrocardiography. Libby P, Bonow RO, Mann DL, et al., editors. Braunwald’s heart disease: a textbook of cardiovascular medicine. 8th ed. Philadelphia. Saunders. 2008:149-94.
7 Ammar KA, Kors JA, Yawn BP, et al. Defining unrecognized myocardial infarction: a call for standardized electrocardiographic diagnostic criteria. Am Heart J. 2004;148(2):277-84. [pmid: 15308997].
8 Holubkov R, Pepine CJ, Rickens C, et al. Electrocardiogram abnormalities predict angiographic coronary artery disease in women with chest pain: results from the NHLBI WISE Study. Clin Cardiol. 2002;25(12):553-8. [pmid: 12492124].
9 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. 1991;11(2):88-94. [pmid: 1907710].
10 Whiting P, Harbord R, Kleijnen J, et al. No role for quality scores in systematic reviews of diagnostic accuracy studies. BMC Med Res Methodol. 2005;5:19. [pmid: 15918898].
11 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
12 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
13 Harbord RM, Whiting P, Sterne JA, et al. An empirical comparison of methods for meta-analysis of diagnostic accuracy showed hierarchical models are necessary. J Clin Epidemiol. 2008;61(11):1095-103. [pmid: 19208372].
14 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
15 Tonino PA, De Bruyne B, Pijls NH, et al. Fractional flow reserve versus angiography for guiding percutaneous coronary intervention. N Engl J Med. 2009;360(3):213-24. [pmid: 19144937].
16 Alderman EL, Corley SD, Fisher LD, et al. Five-year angiographic follow-up of factors associated with progression of coronary artery disease in the Coronary Artery Surgery Study (CASS). CASS Participating Investigators and Staff. J Am Coll Cardiol. 1993;22(4):1141-54. [pmid: 8409054].
17 Boden WE, O’Rourke RA, Teo KK, et al. Optimal medical therapy with or without PCI for stable coronary disease. N Engl J Med. 2007;356(15):1503-16. [pmid: 17387127].
18 Chaitman BR, Fisher LD, Bourassa MG, et al. Effect of coronary bypass surgery on survival patterns in subsets of patients with left main coronary artery disease. Report of the Collaborative Study in Coronary Artery Surgery (CASS). Am J Cardiol. 1981;48(4):765-77. [pmid: 7025604].
19 Patel MR, Dehmer GJ, Hirshfeld JW, et al. ACCF/SCAI/STS/AATS/AHA/ASNC 2009 Appropriateness Criteria for Coronary Revascularization: a report by the American College of Cardiology Foundation Appropriateness Criteria Task Force, Society for Cardiovascular Angiography and Interventions, Society of Thoracic Surgeons, American Association for Thoracic Surgery, American Heart Association, and the American Society of Nuclear Cardiology Endorsed by the American Society of Echocardiography, the Heart Failure Society of America, and the Society of Cardiovascular Computed Tomography. J Am Coll Cardiol. 2009;53(6):530-53. [pmid: 19195618].
20 Ringqvist I, Fisher LD, Mock M, et al. Prognostic value of angiographic indices of coronary artery disease from the Coronary Artery Surgery Study (CASS). J Clin Invest. 1983;71(6):1854-66. [pmid: 6863543].
21 Bashore TM, Bates ER, Berger PB, et al. American College of Cardiology/Society for Cardiac Angiography and Interventions Clinical Expert Consensus Document on cardiac catheterization laboratory standards. A report of the American College of Cardiology Task Force on Clinical Expert Consensus Documents. J Am Coll Cardiol. 2001;37(8):2170-214. [pmid: 11419904].
22 Gibbons RJ, Balady GJ, Bricker JT, et al. ACC/AHA 2002 guideline update for exercise testing: summary article. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1997 Exercise Testing Guidelines). [erratum appears in J Am Coll Cardiol. 2006 Oct 17;48(8):1731]. J Am Coll Cardiol. 2002;40(8):1531-40. [pmid: 12392846].
23 Klocke FJ, Baird MG, Lorell BH, et al. ACC/AHA/ASNC guidelines for the clinical use of cardiac radionuclide imaging--executive summary: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (ACC/AHA/ASNC Committee to Revise the 1995 Guidelines for the Clinical Use of Cardiac Radionuclide Imaging). J Am Coll Cardiol. 2003;42(7):1318-33. [pmid: 14522503].
24 Kadish AH, Buxton AE, Kennedy HL, et al. ACC/AHA clinical competence statement on electrocardiography and ambulatory electrocardiography. A report of the ACC/AHA/ACP-ASIM Task Force on Clinical Competence (ACC/AHA Committee to Develop a Clinical Competence Statement on Electrocardiography and Ambulatory Electrocardiography). J Am Coll Cardiol. 2001;38(7):2091-100. [pmid: 11738321].
25 American College of Radiology, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, et al. ACCF/ACR/SCCT/SCMR/ASNC/NASCI/SCAI/SIR 2006 appropriateness criteria for cardiac computed tomography and cardiac magnetic resonance imaging. A report of the American College of Cardiology Foundation Quality Strategic Directions Committee Appropriateness Criteria Working Group. J Am Coll Radiol. 2006;3(10):751-71. [pmid: 17412166].
26 Miller JM, Rochitte CE, Dewey M, et al. Diagnostic performance of coronary angiography by 64-row CT. N Engl J Med. 2008;359(22):2324-36. [pmid: 19038879].
27 Scirica BM, Morrow DA, Scirica BM, et al. Troponins in acute coronary syndromes. Semin Vasc Med. 2003;3(4):363-74. [pmid: 15199443].
28 Braunwald E, Antman EM, Beasley JW, et al. ACC/AHA guidelines for the management of patients with unstable angina and nonST-segment elevation myocardial infarction. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on the Management of Patients With Unstable Angina). [erratum appears in J Am Coll Cardiol 2001 Jul;38(1):294–5]. J Am Coll Cardiol. 2000;36(3):970-1062. [pmid: 10987629].
29 Achar SA, Kundu S, Norcross WA, et al. Diagnosis of acute coronary syndrome. Am Fam Physician. 2005;72(1):119-26. [pmid: 16035692].
30 Bennett NM, Paris MC. Cardiovascular problems: coronary artery disease. Black ER, Bordley DR, Tape TG, et al., editors. Diagnostic strategies for common medical problems. 2nd ed. Philadelphia. Amercian College of Physicians-American Society of Internal Medicine. 1999:47-60.
31 Guidelines for cardiac exercise testing. ESC Working Group on Exercise Physiology, Physiopathology and Electrocardiography. Eur Heart J. 1993;14(7):969-88. [pmid: 8375424].
32 Birdwell BG, Raskob GE, Whitsett TL, et al. The clinical validity of normal compression ultrasonography in outpatients suspected of having deep venous thrombosis. Ann Intern Med. 1998;128(1):1-7. [pmid: 9424975].
33 Kearon C, Julian JA, Newman TE, et al. Noninvasive diagnosis of deep venous thrombosis. McMaster Diagnostic Imaging Practice Guidelines Initiative. Ann Intern Med. 1998;128(8):663-77. [pmid: 9537941].
34 Grube E, Bootsveld A, Yuecel S, et al. Computerized two-lead resting ECG analysis for the detection of coronary artery stenosis. Int J Med Sci. 2007;4(5):249-63. [pmid: 18026565].
35 Grube E, Bootsveld A, Buellesfeld L, et al. Computerized two-lead resting ECG analysis for the detection of coronary artery stenosis after coronary revascularization. Int J Med Sci. 2008;5(2):50-61. [pmid: 18345283].
36 Menown IB, Patterson RS, MacKenzie G, et al. Body-surface map models for early diagnosis of acute myocardial infarction. J Electrocardiol. 1998;31(Suppl):180-8. [pmid: 9988026].
37 Menown IB, Allen J, Anderson JM, et al. ST depression only on the initial 12-lead ECG: early diagnosis of acute myocardial infarction. Eur Heart J. 2001;22(3):218-27. [pmid: 11161933].
38 McClelland AJ, Owens CG, Menown IB, et al. Comparison of the 80-lead body surface map to physician and to 12-lead electrocardiogram in detection of acute myocardial infarction. Am J Cardiol. 2003;92(3):252-7. [pmid: 12888126].
39 Navarro C, Owens C, Riddell J, et al. The use of calculated epicardial potentials improves significantly the sensitivity of a diagnostic algorithm in the detection of acute myocardial infarction. J Electrocardiol. 2003;36(Suppl):127-32. [pmid: 14716613].
40 Owens CG, McClelland AJ, Walsh SJ, et al. Prehospital 80-LAD mapping: does it add significantly to the diagnosis of acute coronary syndromes?. J Electrocardiol. 2004;37(Suppl):223-32. [pmid: 15534846].
41 Owens C, McClelland A, Walsh S, et al. Comparison of value of leads from body surface maps to 12-lead electrocardiogram for diagnosis of acute myocardial infarction. Am J Cardiol. 2008;102(3):257-65. [pmid: 18638583].
42 Weiss MB, Narasimhadevara SM, Feng GQ, et al. Computer-enhanced frequency-domain and 12-lead electrocardiography accurately detect abnormalities consistent with obstructive and nonobstructive coronary artery disease. Heart Dis. 2002;4(1):2-12. [pmid: 11975826].
43 Hosokawa J, Shen JT, Imhoff M. Computerized 2-lead resting ECG analysis for the detection of relevant coronary artery stenosis in comparison with angiographic findings. Congest Heart Fail. 2008;14(5):251-60. [pmid: 18983288].
44 Hoekstra JW, O’Neill BJ, Pride YB, et al. Acute detection of ST-elevation myocardial infarction missed on standard 12-Lead ECG with a novel 80-lead real-time digital body surface map: primary results from the multicenter OCCULT MI trial. Ann Emerg Med. 2009;54(6):779-788.e1. [pmid: 19766352].
45 Bossuyt PM, Irwig L, Craig J, et al. Comparative accuracy: assessing new tests against existing diagnostic pathways. [erratum appears in BMJ. 2006 Jun 10;332(7554):1368]. BMJ. 2006;332(7549):1089-92. [pmid: 16675820].
46 Bojovic B, Hadzievski L, Vukcevic VD, et al. Visual 3Dx: algorithms for quantitative 3-dimensional analysis of ECG signals. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:6751-4. [pmid: 19963685].
47 Solomon AJ, Tracy CM. The signal-averaged electrocardiogram in predicting coronary artery disease. Am Heart J. 1991;122(5):1334-9. [pmid: 1950997].
48 Strobeck JE, Shen JT, Singh B, et al. Comparison of a two-lead, computerized, resting ECG signal analysis device, the MultiFunction-CardioGram or MCG (a.k.a. 3DMP), to quantitative coronary angiography for the detection of relevant coronary artery stenosis (>70%) - a meta-analysis of all published trials performed and analyzed in the US. Int J Med Sci. 2009;6(4):143-55. [pmid: 19381351].