# Executive Summary

## Introduction

While chest pain is a common symptom of patients presenting to clinics and emergency wards, only about six percent of patients presenting to the emergency room with acute chest pain are ultimately diagnosed with myocardial infarction. Identification of which patients with chest pain are experiencing myocardial ischemia or infarction is critical, since a delay in diagnosis can impede the application of effective therapies, such as thrombolytic agents or percutaneous coronary intervention (PCI). Tests that identify patients with significant coronary artery disease (CAD) serve as a means of facilitating aggressive implementation of secondary preventive strategies. Thus, accurate diagnostic tests and protocols are imperative in order to properly triage patients presenting with chest pain.

In patients where CAD is suspected – either because of the presence of risk factors for CAD or because of symptoms that may represent manifestations of CAD (e.g., chest pain) – the standard electrocardiogram (ECG) is one of the most commonly performed tests. The ECG is nearly universally available, noninvasive, easy to perform, relatively inexpensive, and can usually be completed in less than 10 minutes. However, a resting ECG has limited sensitivity for detecting CAD.

New devices that seek to improve ECG capabilities have been proposed – specifically, devices that are potentially capable of detecting significant CAD or myocardial ischemia. An enhanced ECG-based test might demonstrate greater positive or negative predictive values, thereby limiting the harms associated with delays in treatment, or providing the diagnostic information necessary to avoid invasive diagnostic or therapeutic interventions.

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Duke Evidence-based Practice Center (Contract No. HHSA 290-2007-10066I). The purpose of the technology assessment is to summarize the available clinical and scientific evidence on ECG-based signal analysis technologies for evaluating patients with suspected CAD. Some ECG-based technologies have been used for other purposes (e.g., detection of malignant arrhythmias), but these are not the focus of the current report. Rather, this report will concentrate on commercially available ECG-based signal analysis technologies to inform AHRQ and CMS about the utility of these emerging technologies for diagnosing CAD.

We synthesized the existing literature on these technologies in response to the following key questions:

- Key Question 1:
  a. What devices and methods for ECG-based signal analysis are being used or are proposed to be used for diagnosis of CAD? What is the FDA status of these devices?
  b. What are considered the “gold standard” tests for the diagnosis of CAD and what are their strengths and limitations?
- Key Question 2:
  a. What is the evidence for inter-rater, intra-rater, intra-patient, and intra-device variability?
  b. What is the evidence for diagnostic test performance compared to the reference standard used in the study? What factors (confounders) affected test sensitivity and specificity?
  c. What is the evidence that ECG-based signal analysis technologies impact diagnostic decisionmaking?
  d. What is the evidence that ECG-based signal analysis technologies impact patient outcomes?

## Methods

We developed an analytic model based on principles from Fryback and Thornbury’s hierarchical model of diagnostic efficacy that guided our research questions, search strategy, data abstraction elements, and evaluations. We conducted a systematic search of the English-language literature indexed in PubMed^®^ and searched the U.S. Food and Drug Administration (FDA) web site, Google™, and online patents. We sought to identify devices that improved CAD diagnosis through the use of signal analysis, spectral analysis, or other forms of advanced data transformation.

The purpose of the literature review for Key Question 1 was to identify potentially relevant devices and methods, while the purpose of the literature review for Key Question 2 was to synthesize the available scientific evidence that pertains to ECG-based signal analysis technologies that are potentially applicable to the diagnosis of CAD. The general eligibility criteria included:

- Relevant device.
- Tested on outpatients at low to intermediate risk for CAD.
- Relevant outcomes reported, including performance characteristics, effects on diagnostic or treatment decisions, or effects on patient outcomes.
- N > 30.

One investigator abstracted data from each included study into an evidence table and assessed study quality; the results were then checked for accuracy by a second investigator. Since few studies met eligibility criteria, we broadened the criteria to include studies evaluating individuals at higher risk for CAD (such as inpatients or those scheduled for cardiac catheterizations). Although these studies may have had poor applicability to the target population, they provided some relevant information. Data were synthesized qualitatively and, when appropriate, using quantitative methods. We excluded from formal analysis those devices for which we could not find evidence of commercial availability.

## Results

### Key Question 1a Devices and Methods for ECG-based Signal Analysis

The horizon scan identified seven potentially relevant devices, including three that use body surface mapping and one that uses mathematical signal analysis. Of the seven devices, only the PRIME ECG^®^ by Heartscape Technologies (body surface mapping) and the 3DMP™/MCG™/mfEMT™ by Premier Heart (mathematical signal analysis; referred to here simply as the 3DMP) are cleared for marketing by the FDA and commercially available. One body surface mapping device (Visual ECG/Cardio3KG™ by NewCardio) is commercially available but not cleared; the other devices are not commercially available.

### Key Question 1b Gold Standard Tests for Diagnosing CAD

Coronary angiography (CA) remains the best reference standard for diagnosing CAD. Through interrogation and identification of the coronary anatomy, CA is currently the best available test to identify which patients may benefit from surgical intervention, medical management, or both. Among low-risk patients who are typically not referred for CA but undergo clinical observation and/or noninvasive testing instead, several noninvasive diagnostic tests have served as an acceptable reference standard. In these patients, results from noninvasive tests have correlated with the incidence of cardiovascular events. In particular, stress tests (with or without imaging) provide clinicians with incremental risk prediction that informs management and treatment decisions. Stress tests also provide prognostically important data that have been associated with patient outcomes such as exercise capacity, hemodynamic response, and magnitude of ST-segment abnormalities.

Resting ECGs, however, are not acceptable reference standards for the diagnosis of CAD, due mainly to their low sensitivity and specificity in both symptomatic and asymptomatic patients. As a result, new technologies for diagnosing CAD are most appropriately compared to the reference standard of CA or, at the very least, acceptable noninvasive reference standards such as stress imaging. Table ES summarizes our conclusion that CA remains the preferred reference standard for the diagnosis of CAD, while exercise stress testing with imaging serves as an acceptable reference standard. Appropriate use of biomarkers is an acceptable reference standard for the diagnosis of acute myocardial infarction, but not for CAD. The standard resting 12-lead ECG is not an acceptable reference standard due to its relatively poor accuracy in diagnosing low- to intermediate-risk patients with CAD.

Table ES Potential reference standards for CAD diagnosis

Level of reference standard | Coronary artery disease
Preferred | Coronary angiography
Acceptable | Stress testing with imaging
Unacceptable | Imaging studies without exercise or pharmacological stress Resting 12- lead ECG Stress testing with ECG
Incomplete | Biomarkers (applicable only for identifying myocardial injury)

Abbreviations: CAD = coronary artery disease; ECG = electrocardiogram

### Key Question 2a What is the evidence for inter-rater, intra-rater, intra-patient and intra-device reliability?

Two studies meeting expanded eligibility criteria evaluated the 3DMP device in subjects scheduled for cardiac catheterization. These studies evaluated test and re-test reliability in a subset of 83 subjects using a 0 to 20 severity score. Study quality was good, but the original ECG electrodes were left in place for the second recording, eliminating electrode placement as a source of variability. Of the 83 subjects, the severity score was identical across the two tests in 68 (81.9 percent). Significantly, 11 of the disagreements differed by only a single point. For one study, the authors reported that only one of the nine disagreements would have changed the overall interpretation from normal to abnormal. The data presented are not sufficient to calculate measures of chance-corrected agreement that provide a better estimate than simple agreement.

No data on reliability were identified for the other devices.

### Key Question 2b What is the evidence for diagnostic test performance compared to the criterion standard used in the study? What factors (confounders) affected test sensitivity and specificity?

The FDA-cleared PRIME ECG was evaluated in six studies involving 2345 subjects with chest pain; five of these studies also evaluated the 12-lead ECG. Subjects were recruited from emergency departments, medical wards, or mobile coronary care units (CCUs) in Ireland, settings that may serve a population with a higher risk of acute myocardial ischemia than the target population for this report. The PRIME ECG was compared to cardiac biomarkers for the presence of acute myocardial injury. A bivariate random-effects model was used to combine results. The likelihood ratio positive (LR+) was 5.0 (95 percent CI 3.5 to 6.5) and likelihood ratio negative (LR−) was 0.37 (0.30 to 0.43); studies were statistically heterogeneous.

We performed a sensitivity analysis excluding the initial study, which clearly used a different diagnostic algorithm, and a second study with a very small sample size that was disproportionately weighted in the random-effects meta-analysis. The LR+ (6.5; 95 percent CI 4.2 to 8.8) and LR− (0.33; 0.28 to 0.39) were not substantially changed; statistical heterogeneity remained significant. Using these latter estimates of test performance, an abnormal PRIME ECG test in a patient with a pretest probability for clinically significant CAD of 50 percent would yield a posttest probability of 87 percent. A normal PRIME ECG would yield a posttest probability of 25 percent. The performance characteristics of the 12-lead ECG were neither clinically nor statistically significantly different from the PRIME ECG.

For the FDA-cleared 3DMP, no studies met our inclusion criteria, but four studies enrolled subjects at high risk or with known CAD, thereby meeting expanded inclusion criteria. Using a threshold of ≥ 4.0 on the 0 to 20 severity score, the 3DMP was evaluated in 920 subjects scheduled for coronary angiography. The summary estimate for LR+ was 5.3 (95 percent CI 3.8 to 6.9) and for LR− was 0.09 (0.04 to 0.13). A single low-quality study compared the 3DMP to 12-lead ECG; the 3DMP was more sensitive (97 percent versus 75 percent) and more specific (72 percent versus 41 percent) than the ECG. For a patient with a pretest probability for clinically significant CAD of 50 percent, a 3DMP score of 4 would yield a posttest probability of 84 percent. A 3DMP score < 4 would yield a posttest probability of 8 percent. Since there were differences in the subjects and reference standard, these results are not directly comparable to the PRIME ECG, or to the 12-lead ECG results discussed above.

### Key Question 2c What is the evidence that ECG-based signal analysis technologies impact diagnostic decisionmaking?

Our search strategy did not identify any eligible studies pertinent to this question.

### Key Question 2d What is the evidence that ECG-based signal analysis technologies impact patient outcomes?

We identified a single study that addressed this question. It tested the hypothesis that individuals with ST elevation myocardial infarction (STEMI) detected only by the PRIME ECG would have similar angiographic pathology and similar mortality and morbidity rates to those with STEMI detected by standard ECG. Adults (n = 1830) presenting to 12 tertiary care emergency departments with chest pain or symptoms suspicious for acute coronary syndrome who were at moderate to high risk for adverse cardiovascular outcomes were enrolled. Subjects underwent testing with a standard 12-lead ECG and the PRIME ECG, but direct comparisons were not made. Of the 1830 subjects enrolled, 91 (4.97 percent) had STEMI by standard ECG, and 25 of the remaining 1736 patients (1.44 percent) had STEMI by PRIME ECG. A subset of those with PRIME ECG STEMI (n = 14) underwent coronary angiography which showed similar anatomy to those with STEMI by standard ECG. Clinical outcomes at 30 days did not differ significantly between those with STEMI by standard ECG versus PRIME ECG only, but sample sizes were small, and the study was not powered to detect a clinically significant difference. These results provide preliminary data that the PRIME ECG can detect a small subset of patients without STEMI by standard ECG who have angiographic and clinical outcomes that are similar to individuals with STEMI by standard ECG.

## Discussion and Conclusions

There is currently little available evidence that pertains to the utility of ECG-based signal analysis technologies as a diagnostic test among patients at low to intermediate risk of CAD who present in the outpatient setting with the chief complaint of chest pain. The limited evidence that is available demonstrates proof of concept, particularly for the PRIME ECG and 3DMP devices. Further research is needed to better characterize the performance characteristics of these devices to determine in what circumstances, if any, these devices might precede, replace, or add to the standard ECG for the diagnosis of CAD among patients who present with chest pain in the outpatient setting. The randomized controlled trial (RCT) study design is best suited for evaluating the impact that ECG-based signal analysis technologies may have on clinical decisionmaking and patient outcomes, but there are indirect approaches that might be applied to answer these questions.