# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Francesco Buccelletti, M.D.
  Department of Emergency Medicine
  Catholic University of Sacred Heart
  Rome, Italy
- Stephen C. Hammill, M.D.
  Director, Electrocardiography Laboratory
  Mayo Clinic
  Rochester, Minnesota
- Jeffrey A. Tabas, M.D.
  Associate Professor of Emergency Medicine
  University of California, San Francisco (UCSF) School of Medicine
  San Francisco, California