# Acknowledgements

The authors gratefully acknowledge the contributions of: R. Julian Irvine, M.C.M., and Karen Greenleaf, B.S., Project Coordinators; Connie M. Schardt, M.L.S., Duke University Medical Center Librarian; David L. Simel, M.D., M.H.S., diagnostic test meta-analyst; Rebecca Gray, D.Phil., EPC Editor; and Erin LoFrese, M.S., Outcomes Research and Assessment Editor.