# Discussion

## Summary of Findings

The horizon scan identified seven ECG-based devices used to diagnose CAD or detect acute myocardial infarct. Of these devices, the PRIME ECG, the Cardio3KG, and the 3DMP appear to be commercially available at this time, with only the PRIME ECG and 3DMP having obtained FDA clearance for marketing. Our original search of the English-language literature identified only six studies that reported on performance characteristics of a single ECG-based signal analysis device (the PRIME ECG) in outpatients with chest pain. An expanded search strategy that allows for the inclusion of studies on patients at higher risk of CAD identified an additional seven studies.

The PRIME ECG appears to be the only relevant device in the published literature that has been evaluated in patients with acute chest pain, but it was compared to an incomplete reference standard that only detected acute myocardial injury. Even these studies enrolled subjects at higher risk than the target population for this report. The available published evidence suggests that the PRIME ECG demonstrates slightly more favorable performance characteristics compared to the standard ECG among patients with ischemic-type chest pain, with myocardial injury as assessed by biomarkers as the reference standard. We were unable to identify any published evidence about the performance characteristics of the PRIME ECG among the patient population of interest (e.g., persons at low to intermediate risk of CAD).

Limited published evidence suggests that the 3DMP may have adequate retest reliability, but studies are needed that fully evaluate inter-rater reliability and include electrode placement as a potential source of variability. Test performance characteristics for this device appear to be generally good, but the findings from the published studies do not apply to the target population for this report.

## Limitations of Current Studies

Our search strategy did not identify any eligible studies of patients at low to intermediate risk of CAD who presented in the outpatient setting with chest pain. The evidence summarized in this report was obtained from studies that included patients recruited from urgent care or hospital settings who were generally at high risk of CAD, or who had known CAD. There is, therefore, insufficient evidence to address directly the key questions as they pertain to the patient population of interest.

The evidence summarized in this report may still be informative, however, with the caveat that selection of a patient population with high prevalence of CAD may result in a cohort of patients with higher disease severity. An enriched prevalence may affect how a test is interpreted (most likely by lowering the implicit threshold defining a positive test result). Both of these effects (higher prevalence and a tendency to lower the threshold for an abnormality) can result in an overestimate of test performance. Furthermore, potential differences in patient characteristics such as body habitus, comorbid conditions, or prevalence of conduction abnormalities, might affect test performance.

The studies identified by our search strategy reported exclusively on test performance. They did not provide direct evidence pertaining to the impact of ECG-based signal analysis technologies on decisionmaking or patient outcomes. Additional information that is lacking in the published literature but that would help in the evaluation of ECG-based signal analysis technologies includes practical considerations, such as how long it takes to administer the tests and obtain interpretable data, the training required to operate the equipment and interpret the findings, the extent of ancillary support or additional space requirements, and whether it is feasible to administer the test to certain subgroups of patients, such obese or very thin patients or patients with certain comorbid conditions. Another limitation of the current studies is that they do not allow for comparative analysis of the performance between the new devices (e.g., 3DMP versus PRIME ECG) due to the use of different reference standards and substantial diversity in study populations.

## Strengths and Limitations of this Review

The strengths of our search strategy include a gray literature search to identify relevant devices. Intentionally, we did not use electronic search filters, given that filters often inadvertently exclude relevant studies. The limitations of our search strategy include: (1) an absence of standardized, widely accepted, reliable, and validated methods for searching the gray literature; (2) the fact that some of the pertinent evidence is proprietary and not accessible via manufacturers’ websites, and that we did not request information from manufacturers directly; and (3) in general, identifying test accuracy studies is more difficult than identifying studies of therapeutic interventions.

We relied primarily on published studies to identify potentially relevant devices. Peer-reviewed publications, however, do not always include complete information about investigational devices or methods. We therefore had difficulty tracking the lineage of both the devices and the proprietary data transformation algorithms that are central to signal analysis technologies. We do not know if the devices or the mathematical algorithms underlying the technology have remained constant over time. This problem may be common to formal evaluations of medical devices for which potentially significant changes over time are not documented in the public record.

## Future Research

Bossuyt and colleagues have proposed a framework for new test evaluation that may help guide future research pertaining to ECG-based signal averaging technologies.45 This framework considers new diagnostic tests as either potential replacement, triage, or add-on tests. Bossuyt argues that in order to determine if a new test can replace an existing one, the diagnostic accuracy of both tests need to be compared in the same patient sample, since the sensitivity and specificity of a test can vary across subgroups. Furthermore, the new tests should be compared to existing tests using the same reference standard. The paired test evaluation that is used to determine performance characteristics has advantages over a randomized controlled trial (RCT) design, including a requirement of fewer subjects than an RCT.

ECG-based signal analysis technologies may be more accurate than the 12-lead ECG. According to the evidence summarized in this report, the PRIME ECG and 3DMP may demonstrate slightly higher sensitivity than the standard 12-lead ECG. This suggests that ECG-based signal analysis devices could potentially serve to complement the findings from standard 12-lead ECGs as “add-on” tests. Add-on tests can be used in a subgroup of patients where diagnosis needs clarification. For example, add-on tests could be used to further evaluate a patient who presents with a normal ECG, but nonetheless is having active chest pain. An add-on test may be able to help clarify whether or not such a patient is having chest pain due to cardiac etiologies that are undetected by the 12-lead ECG, or if this patient is having chest pain due to a noncardiac cause. Add-on test strategies are attractive because they are noninvasive and accurate alternatives to the standard 12-lead ECG. However, these tests are less attractive than the standard 12-lead ECG, due to the fact that they are more expensive, more time consuming for medical personnel, and currently have limited availability in clinical settings. The add-on test strategy can potentially increase the sensitivity of the existing testing standards, but possibly at the expense of specificity. Study designs that are more efficient than the fully paired evaluation can be used to evaluate this add-on strategy.

Currently available published literature on ECG-based signal analysis technologies does not provide answers to the key questions surrounding the debate over whether or not these technologies impact diagnostic decisionmaking or patient outcomes. However, these questions may best be addressed by RCTs. Depending on the specific question, a number of trial designs could be considered, including a clinical trial of test-positive patients, with clinicians randomized to disclosure of test results. Another alternative would be a trial that randomizes patients to a test strategy that uses conventional testing versus a test strategy that uses a new device. Finally, another but less direct approach, would be to link evidence on test performance to evidence on the effects of interventions (e.g., anti-anginals or PCI) in the population of interest. This final example is sometimes employed by the United States Preventive Services Task Force for evaluation of screening tests. This less direct approach is more subject to bias due to the underlying assumptions that are inherent in creating these linkages.

## Summary

There is currently little available evidence that pertains to the utility of ECG-based signal analysis technologies as a diagnostic test among patients at low to intermediate risk of CAD who present in the outpatient setting with the chief complaint of chest pain. The limited evidence that is available demonstrates proof of concept, particularly for the 3DMP and PRIME ECG devices. Further research is needed to better characterize the performance characteristics of these devices to determine in what circumstances, if any, these devices might precede, replace, or add to the standard ECG in test strategies for the diagnosis of CAD in the patient population of interest. The RCT study design is best suited for evaluating the impact that ECG-based signal analysis technologies may have on clinical decisionmaking and patient outcomes, but there are indirect approaches that might be applied to answer these questions.