# Results

## Key Question 1a Devices and Methods for ECG-based Signal Analysis

### Overview of Devices Identified

Results of the horizon scan and gray literature search are summarized in Appendix B. The horizon scan identified seven potentially relevant devices (Table 1):

Table 1 ECG-based signal analysis devices identified by the horizon scan

Device name | Manufacturer | Commercially available^*^ | FDA cleared^†^ | Device type
FDX-6521 | Fukuda Denshi | No | No | SA
VCM-3000 | Fukuda Denshi | No | No | BSM
Prime ECG^®^ | Heartscape | Yes | Yes | BSM
Visual ECG/Cardio3KG™ | New Cardio | Yes | No | BSM
3DMP™/MCG™/mfEMT™ | Premier Heart | Yes | Yes | MA
Model 1200 | Arrhythmia Research Technology | No | No | SA
Predictor™ | Corazonix | No | Yes | SA

Abbreviations: BSM = body surface mapping; ECG = electrocardiogram; FDA = U.S. Food and Drug Administration; MA = mathematical analysis; SA = signal-averaging.

* Commercially available from a device manufacturer.

† Cleared for marketing the by FDA.

A device may be cleared for marketing by the FDA when it is determined to be substantially similar to a predicate device. Of the devices listed in Table 1, only the PRIME ECG^®^ and 3DMP™/MCG™/mfEMT™ (referred to hereafter as the 3DMP) are currently cleared by the FDA and commercially available. Both devices received clearance for marketing for the indication of recording ECG signals. The Predictor is cleared by the FDA, but apparently no longer available. Of the four devices that are not FDA cleared, the FDX-6521 and VCM-3000 manufactured by Fukuda Denshi and the 1200 EPX by Arrhythmia Research Technology appear to be no longer commercially available; the Visual ECG/Cardio3KG™ (referred to hereafter as the Cardio3KG) manufactured by NewCardio is commercially available. The three commercially available devices include two body surface mapping devices (PRIME ECG and Cardio3KG) and one device that uses mathematical analysis (3DMP).

### Body Surface Mapping Devices

The PRIME ECG utilizes a disposable vest that incorporates additional electrodes to measure electrocardiac activity from the front, back, and sides of the torso to create an “80-lead ECG.” ECG recordings showing ST segment elevation, suggestive of acute myocardial injury, are represented on a torso map to localize and demonstrate the extent of injury. Areas on the torso map corresponding to regions of myocardium demonstrating ST segment elevation are color coded red. Areas of ST depression are blue, and neutral areas are green.

The Cardio3KG extracts data from the standard 12-lead ECG to generate a three-dimensional representation of cardiac electrical activity. Without requiring additional electrodes, this device transforms 12-lead ECG information into X, Y, and Z components of the heart vector, normalizes the lead vectors, and displays virtual lead voltages on a three-dimensional model of the heart.

### Mathematical Analysis Devices

The 3DMP device (also referred to as the MCG or mfEMT) utilizes ECG data from two of the 12 standard leads (leads II and V5) to perform frequency and time domain analyses. Recordings for over 82 seconds are amplified, digitized, encrypted, and sent securely over the internet to Premier Heart Datacenter, where signal analysis and mathematical transformations are performed to derive indices that, in particular patterns, may signify the presence of disease. The data are compared to a large empirical database to determine a "Final Diagnosis" and "Severity Score"; these are then securely reported back over the internet within several minutes to the requesting provider. We were unable to determine the details of the proprietary severity scoring.

## Key Question 1b Gold Standard Tests for Diagnosing CAD

### Overview

Diagnostic tests for CAD can be categorized as either invasive or noninvasive. Invasive tests include cardiac catheterization with coronary angiography and postmortem autopsy. Noninvasive tests utilize technologies that permit either visualization of the heart and corresponding vasculature, or interpretation of electrical signals generated by a beating heart. With the exception of an autopsy, no invasive or noninvasive test yields a definitive diagnosis of CAD. Rather, these tests are used to infer the presence of CAD by identifying coronary artery occlusion, irregular electrical signals, abnormal heart wall motion, or damage to myocardial cells. Our discussion emphasizes the options for reference standards that might be considered in research studies to evaluate a new diagnostic technology.

### Invasive Testing – Coronary Angiography

Description. Invasive coronary angiography (CA) involves the insertion and manipulation of slender catheter tubes from a percutaneously accessed arterial site (most commonly via the femoral artery) to the origin of the coronary arteries. Iodinated contrast agents are injected through these tubes, lighting up the arterial structure, and allowing x-ray images to be obtained. These images are then used in determining a diagnosis of and/or treatment for CAD. The cineangiograms are the recorded real-time X-ray images of the epicardial coronary arteries. These images are subsequently reviewed by the physician to determine the optimal management strategy for the patient. Lesions that obstruct 70 percent or more of the coronary lumen significantly restrict coronary blood flow and may cause functional obstruction (e.g., angina or angina-like symptoms). The traditional cutpoint of 70 percent obstruction is often accepted as the threshold for significant CAD and may prompt revascularization. Nevertheless, data challenging qualitative angiographic grading for revascularization on patient outcomes have recently been reported.15

Strengths. The current role of CA has been to aid in the identification of patients who will benefit clinically from revascularization.16–20 CA can be used in conjunction with contrast ventriculography to determine left ventricular function. CA is the preferred reference standard for diagnosing the severity of obstruction in the coronary arteries, as noninvasive testing currently lacks the sensitivity to exclude left main or multivessel CAD, which are independently associated with poor survival.21–23 CA is generally considered to be the best available method of diagnosing CAD.

Limitations. CA is primarily restricted to identifying the degree of major epicardial vessel luminal stenosis. Furthermore, CA cannot provide information regarding the patient’s exercise capacity, hemodynamic response to exercise, or functional status. Although CA is generally considered a relatively safe procedure, serious complications (including death, myocardial infarction, and embolization) have been reported. The rate of serious complication or death associated with CA is approximately 0.1 percent.21 Finally, of all the frequently used tests for diagnosing CAD, CA is the most expensive.

### Noninvasive Testing

Noninvasive tests are often used in the workup of undifferentiated chest pain in outpatient or acute care settings to provide incremental data and refine the pretest clinical suspicion of CAD. Patients with negative (i.e., normal) findings on noninvasive tests may be triaged to prevention and clinical observation management strategies, whereas patients with positive findings may be referred for CA in order to determine the presence or absence of CAD. Supported by the literature, this approach has been used to refine the selection of patients with the highest likelihood of significant CAD and for whom revascularization may improve clinical outcomes, while at the same time minimizing unnecessary referrals for more expensive and potentially risky invasive testing. Patients with indeterminate or conflicting results on initial noninvasive testing may be triaged to either strategy (prevention and clinical observation or CA) or referred for additional testing. This determination is largely dependent upon the posttest risk assessment by the clinician.

#### A Electrocardiography

Description. The standard clinical ECG detects the electrical field generated by the ion currents in cardiac cells through detection of potential differences on the skin surface. The signal is amplified, filtered, and displayed as a recording which is then interpreted either computationally or by medical personnel.

Strengths. The ECG is inexpensive, universally available, and broadly understood across medical disciplines.

Limitations. The ECG lacks sufficiently high sensitivity for detection of CAD to be considered an adequate reference standard.7,8,24

#### B Cardiac computed tomography

Description. Computed tomographic angiography, or cardiac computed tomography (CCT) uses modified software and hardware to acquire images of the luminal patency of the epicardial coronary arteries after administration of an intravenous contrast agent. Once obtained, the images are reformatted and reviewed for quantitative estimation of luminal narrowing in the coronary artery. If present, luminal narrowing is suggestive of CAD.25,26 Sensitivity is estimated to be 85 percent, and specificity 95 percent

Strengths. CCT provides noninvasive anatomical detail of both the heart and the coronary arteries. CCT can identify unrelated or unsuspected diseases, which may or may not be related to the patient’s symptoms (e.g., lung mass, pulmonary embolus, or aortic dissection). Operating characteristics (sensitivity/specificity) compare well with currently used stress imaging studies.

Limitations. CCT is relatively expensive. The procedure involves radiation exposure and the administration of an intravenous contrast (thus, CCT is not appropriate for patients with renal insufficiency). The procedure does not readily identify CAD in distal segments of the coronary arteries. CCT is a relatively new technology; as such, there is limited information about how information it generates correlates with long-term clinical outcomes.

#### C Biomedical markers

Description. Patients with acute myocardial infarction demonstrate elevations of serum cardiac biomedical markers (biomarkers) such as troponin or creatinine kinase (CK-MB). These values are usually elevated within 6 to 8 hours after onset of myocardial infarction. Elevation of biomarkers carries prognostic value after myocardial infarction; testing for such elevation is, therefore, part of the standard procedure used to diagnose myocardial infarction.

Strengths. Tests of biomarkers are widely available, and results are rapidly and safely obtainable. Interpretation of findings is relatively straightforward. When measured serially, the troponin and CK-MB biomarkers carry high sensitivity (89 to 95 percent) and specificity (95 percent).27–29 Cardiac troponin is favored, since this marker provides greater specificity than CK-MB. However, since troponin results may remain elevated for up to 10 days, CK-MB is useful in assessing the timing of acute myocardial infarction.

Limitations. Biomarkers may be elevated in conditions unrelated to myocardial infarction, so results must be interpreted in the context of clinical presentation and other available test results. Conditions unrelated to myocardial infarction that may contribute to elevated biomarkers include sepsis, pulmonary embolus, renal failure, tachycardia, and valvular heart disease. Biomarkers have no role in screening for, or diagnosing, CAD outside of the presence of acute myocardial infarction.

### Stress Testing

#### A Stress testing with ECG

Description. Exercise, when used as the stressor, can provide both diagnostic and prognostic information in patients with either suspected or known CAD. Both treadmill and bicycle protocols have been used to evaluate exercise time, intensity, and reproducibility of clinical symptoms. The standard 12-lead ECG, along with clinical symptoms and vital signs, is evaluated for changes during exercise. ECG criteria that have been standardized to suggest an abnormal test result rely on the finding of ST segment depression of 0.01mV (1 mm) that is horizontal or down-sloping on three consecutive beats. Patients unable to exercise would normally undergo a pharmacologic “stress” test in conjunction with an imaging modality (see section B, below).

Strengths. Stress testing is generally safe, widely available, well validated, and less costly compared to other forms of cardiac diagnostics. Stress testing can provide useful prognostic data. In a recent meta-analysis of the relevant studies, sensitivity and specificity were 68 percent and 77 percent, respectively, but values are lower among low-risk patients.22 A normal exercise ECG has excellent negative predictive value.

Limitations. Stress testing is associated with relatively high rates of false-positive results in women, and it cannot be reliably interpreted in patients with a variety of different baseline ECG abnormalities. Other limitations include difficult-to-interpret results in the setting of valvular heart disease, left ventricular hypertrophy, left bundle branch block, or patients on certain heart rate lowering medications such as digoxin. Because of its low sensitivity, with correspondingly high likelihood of misclassifying patients, stress testing with ECG alone is not an adequate reference standard for CAD diagnosis.

#### B Stress testing with imaging

Description. The addition of a cardiac imaging component to the standard exercise ECG stress test is intended to improve test specificity by differentiating true-positive from false-positive ST segment depression during exercise. This is achieved through the absence of perfusion abnormalities (as in the case of myocardial perfusion imaging using single photon emission computed tomography) or left ventricular dysfunction (as in the case of stress echocardiography). Patients are typically imaged at baseline and then undergo ECG-monitored exercise, followed by imaging at peak exercise and recovery. Images are obtained for the purposes of detecting myocardial perfusion abnormalities or regional wall motion abnormalities. For single photon emission computed tomography, sensitivity is estimated to be 90 percent and specificity 72 percent.30 Exercise echocardiography is estimated to be 81 percent sensitive and 89 percent specific using stress-induced wall motion abnormalities.30

Strengths. Stress testing with imaging is a well-validated diagnostic test for CAD, with a highly negative predictive value. The procedure is widely available and noninvasive. Results of stress testing with imaging can guide management and treatment recommendations. The procedure is considered an appropriate diagnostic test in patients with known or suspect CAD who are at low to intermediate risk for cardiovascular events.5

Limitations. Stress testing with imaging is relatively expensive, as well as time-intensive. The procedure requires expertise in performance and interpretation. The procedure involves radiation exposure among patients injected with radiopharmaceuticals. Image quality for study interpretation may be limited in patients with suboptimal images due to attenuation artifacts from overlying soft tissue in single photon emission computed tomography, or poor echocardiographic acoustic windows in patients who are obese or who have lung disease.

### Summary

The strengths and limitations of the current diagnostic tests for the evaluation of suspected CAD represent the absence of a “one-size-fits-all” approach for cardiovascular risk assessment. In accordance with clinical guideline recommendations, the selection of the appropriate test must take into account the available expertise for both test performance and accurate test interpretation, while at the same time maximizing patient safety.31 In the research setting, we ideally want the best available reference test. Pragmatic clinical considerations, including guideline recommendations, legitimately influence this choice.

CA remains the best reference standard for diagnosing CAD.21 Through interrogation and identification of the coronary anatomy, CA is currently the best available test to identify which patients may benefit from surgical intervention, medical management, or both. Among low-risk patients who are typically not referred for CA but undergo clinical observation and/or noninvasive testing instead, several noninvasive diagnostic tests have served as an acceptable reference standard. In these patients, results have correlated with the incidence of cardiovascular events. In particular, stress tests (with or without imaging) provide clinicians with incremental risk prediction that informs management and treatment decisions. Stress tests also provide prognostically important data which have been associated with patient outcomes such as exercise capacity, hemodynamic response, and magnitude of ST segment abnormalities.

Resting ECGs, however, are not acceptable reference standards for the diagnosis of CAD, due mainly to their low sensitivity and specificity among both symptomatic and asymptomatic patients.24 As a result, new technologies for diagnosing CAD are most appropriately compared to the reference standard of CA or, at the very least, acceptable reference standards such as stress imaging. In some disorders (e.g., deep venous thrombosis), reference standards with only moderate performance characteristics have been coupled with longitudinal followup for subsequent events to create a more robust standard.32,33 For CAD, a similar approach might couple noninvasive testing with longitudinal followup for coronary events or CAD diagnosis to create a composite reference standard with improved discriminate validity. Table 2 summarizes our conclusion that CA remains the preferred reference standard for the diagnosis of CAD, while exercise stress testing with imaging serves as an acceptable reference standard. Appropriate use of biomarkers is an acceptable reference standard for the diagnosis of acute myocardial infarction, but not for CAD. The standard 12-lead ECG is not an acceptable reference standard due to its relatively poor accuracy in diagnosing low- to intermediate-risk patients with CAD.

Table 2 Potential reference standards for CAD diagnosis

Level of reference standard | Coronary artery disease
Preferred | Coronary angiography
Acceptable | Stress testing with imaging
Unacceptable | Imaging studies without exercise or pharmacological stress Resting 12-lead ECG Stress testing with ECG
Incomplete | Biomarkers (applicable only for identifying myocardial injury)

Abbreviations: CAD = coronary artery disease; ECG = electrocardiogram

## Key Question 2 Evidence on the Use of ECG-based Signal Analysis Technologies for the Diagnosis of Suspected CAD

Of the seven potentially relevant devices identified by the horizon scan, only the PRIME ECG, the 3DMP, and the Cardio3KG are commercially available (Table 1). We did not identify any published studies that reported on the Cardio3KG. The focus of the following discussion will therefore be on the PRIME ECG and the 3DMP.

### Key Question 2a What is the evidence for inter-rater, intra-rater, intra-patient and intra-device reliability?

Unfortunately, no studies evaluating device reliability met our inclusion criteria. However, two studies evaluating the 3DMP device enrolled subjects scheduled for cardiac catheterization and met our expanded eligibility criteria. These studies evaluated test and re-test reliability in a subset of 83 subjects and are summarized in Table 3. Both studies were reported by the same author and compared the 3DMP device to cardiac angiography using a 0 to 20 severity score. Both studies specified a priori a severity score of 4 as abnormal. Study quality was good with two exceptions: (1) subjects were a convenience sample; and (2) selection criteria likely selected for a sample population with greater disease severity than would be seen in the population of interest in this report. Patient characteristics such as body habitus and presence of comorbid medical conditions (e.g., severe chronic obstructive pulmonary disease) that may have influenced test performance were not described. In 83 subjects, a second 3DMP test was performed, blindly interpreted, and compared to the initial test results. However, the original ECG electrodes were left in place for the second recording, eliminating electrode placement as a source of variability. Of the 83 subjects, the severity score was identical in 68 (81.9 percent), and 11 of the disagreements differed by a single point. For the 2007 study, the authors reported that only one of the nine disagreements would have changed the overall interpretation from normal to abnormal. The data presented are not sufficient to calculate measures of chance-corrected agreement such as a kappa, phi, or intra-class correlation statistics. These measures provide a better estimate than agreement alone, by accounting for agreement that occurs simply by chance.

Table 3 Test reliability of the 3DMP^*^

Study | Subjects | Setting | Threshold | Reference | Outcomes
Grube et al., 2007^34^ | Outpatients scheduled for CA – any indication (n = 423); mean age 61.4 (11.1); 258 men, 165 women | German Heart Center | Automatic differential diagnosis based on indices of abnormality; severity score 0–20 | Cardiac angiography: = 50% obstruction in left main or > 70% obstruction in any other coronary artery | Retest reliability: 36/45 identical scores; 3/9 > 1 point difference (1 would have changed from normal to abnormal); 6/9 1 point difference
Grube et al., 2008^35^ | History of prior coronary revascularization procedure, scheduled for CA (n = 172); mean age 63.9 (10); 116 men, 56 women | German Heart Center | Automatic differential diagnosis based on indices of abnormality; severity score 0–20 | Cardiac angiography: = 50% obstruction in left main or > 70% obstruction in any other coronary artery | Retest reliability: 32/38 identical scores; 1/6 > 1 point difference; 5/6 1 point difference

* 3DMP = Multifunction Cardiogram^sm^ (FDA cleared, commercially available, Premier Heart, LLC, Port Washington, NY).

Abbreviation: CA = cardiac angiography

### Key Question 2b What is the evidence for diagnostic test performance compared to the criterion standard used in the study? What factors (confounders) affected test sensitivity and specificity?

Studies meeting inclusion criteria with FDA cleared devices. We identified studies evaluating the performance characteristics of the PRIME ECG. Six studies involving 2345 subjects with chest pain were evaluated using the PRIME ECG (Table 4); five of these studies also evaluated the 12-lead ECG. Subjects were recruited from emergency departments, medical wards, or mobile coronary care units (CCUs) in Ireland. It is unclear whether these mobile CCUs serve a chest pain population similar to that served by U.S. emergency departments, or if they tend to serve patients triaged to be at high risk for acute myocardial ischemia. A study sample with more severe CAD would be expected to bias test performance towards greater sensitivity. Although there was some uncertainty about whether these patients were truly at low to intermediate risk, we decided to treat these studies as if they were. In all but one study,36 selection bias was minimized by enrolling subjects consecutively. The PRIME ECG interpretation appears to have evolved over time. In the initial study,36 a regression model was developed from 28 candidate variables. In later studies, slightly different criteria (sometimes specified a priori and in other instances apparently derived from the data) are described. The variable criteria for an abnormal PRIME ECG could lead to variable performance across studies. Furthermore, criteria derived from the observed data could overestimate accuracy. In all studies, the PRIME ECG was compared to cardiac biomarkers, which serve as a test for myocardial injury. Four studies either used a single set of biomarkers or did not specify the number of sets obtained (at least two sets, 8 hours apart, are needed for an adequate reference standard). Only one study specified that the PRIME ECG was blindly interpreted and compared to the reference standard. Similarly, only one study described the reference standard as blindly interpreted relative to the PRIME ECG. If abnormal ranges for cardiac biomarkers were prespecified, it is unlikely that interpretation would be influenced by the index test results.

Table 4 Studies evaluating performance characteristics of the PRIME ECG^*^

Study | Subjects | Setting | Threshold | Reference | Outcomes
Menown et al., 1998^36^ | Chest pain (n = 760; 125 controls, 635 patients) | Emergency department, medical wards or mobile CCU; controls from WHO screening program | Not specified; developed from 28 variables via logistic regression | Acute MI – criteria not specified | Training set (n = 384) Sensitivity = 80% (132/165) Specificity = 86% (134/156) Validation set (n = 376) Sensitivity = 77% (123/160) Specificity = 85% (131/154)
Menown et al., 2001^37^ | Ischemic type chest pain < 24 hours and 1 mm ST segment depression (n = 54) | Cardiology – via emergency department or mobile CCU | Algorithm: visual display using QRS Y ST-T isointegrals and ST60 isopotential + multivariate model | MI by chest pain > 20 minutes + abnormal biomarkers | Training set (n = 30) Sensitivity = 69% (11/16) Specificity = 71% (10/14) Validation set (n = 24) Sensitivity = 88% (7/8) Specificity = 75% (12/16) ECG (n = 24) Sensitivity =50% (4/8) Specificity = 88% (14/16)
McClleland et al., 2003^38^ | Ischemic type chest pain (n = 103) | Cardiology – via emergency department or mobile CCU | Algorithm: QRS width and axis, QRS and ST-T isointegrals, ST0 and ST60 isopotentials | MI by chest pain > 20 minutes + abnormal biomarkers | Sensitivity = 64% (34/53) Specificity = 94% (47/50) Physician ECG Sensitivity = 45% (24/53) Specificity = 94% (47/50)
Navarro et al., 2003^39^ | Had ECG, BSM, biomarkers (n = 379) | Cardiology – via emergency department or mobile CCU | Algorithm: epicardial - ST0 isopotential from subset of study sample | MI by abnormal biomarkers | Body surface potential Sensitivity = 62% (106/171) Specificity = 80% (166/208) Epicardial potential Sensitivity = 78% (133/171) Specificity = 80% (166/208) Physician ECG Sensitivity = 54% (93/171) Specificity = 97% (202/208)
Owens et al., 2004^40^ | Ischemic type chest pain (n = 294) | Mobile CCU | Cardiologist interpreted using ST0 maxima, ST 60 minima, and vector magnitude | MI by abnormal biomarkers | Sensitivity = 80% (146/182) Specificity = 92% (103/112) ECG Sensitivity = 57% (104/182) Specificity = 94% (105/112)
Owens et al., 2008^41^ | Ischemic type chest pain (n = 755) | Cardiology – via emergency department or mobile CCU | Region specific ST segment elevation on isopotential map | MI by abnormal biomarkers | Sensitivity = 76% (402/529) Specificity = 92% (208/226) ECG Sensitivity = 49% (238/291) Specificity = 92% (208/226)

* PRIME ECG (FDA cleared; commercially available; initially Meridian Medical Technologies, Belfast – now owned by Heartscape Technologies, Columbia MD).

Abbreviations: BSM = body surface mapping; CCU = coronary care unit; ECG = electrocardiogram; MI = myocardial infarction; WHO = World Health Organization.

We used a bivariate random-effects model to combine results across the six included studies (Table 5). Studies were statistically heterogeneous for the LR+ (Q = 25.6, df = 5, p < 0.001) and for the LR− (Q = 30.0, df = 5, p < 0.001; I^2^ = 80.5 percent). The summary estimate for the LR+ was 5.0 (CI 3.5 – 6.5) and for the LR− was 0.37 (95 percent CI 0.30 to 0.43). We performed a sensitivity analysis excluding two studies, namely, the initial study that most clearly used a different diagnostic algorithm36 and a second study with a very small sample size that was disproportionately weighted in the random effects meta-analysis.37 The remaining studies were heterogeneous for the LR+ (Q = 7.1, df = 3, p = 0.07, I^2^ = 57.6 percent) and LR− (Q = 11.8, df = 3, p = 0.008, I^2^ = 74.6 percent). The LR+ (6.5; 95 percent CI 4.2 to 8.8) and LR− (0.33; 0.28 to 0.39) were not substantially changed. Using these latter estimates of test performance, an abnormal PRIME ECG test in a patient with a pretest probability for clinically significant CAD of 50 percent, would yield a posttest probability of 87 percent. A normal PRIME ECG would yield a posttest probability of 25 percent. For the five studies that also evaluated the 12-lead ECG, we computed performance characteristics in the same manner (Table 6), excluding the study with a very small sample size.37 There was significant heterogeneity for the LR− (Q = 11.8, df = 3, p = 0.02), but not for the LR+ (Q = 7.1, df = 3, p = 0.18). The 12-lead ECG had a summary LR+ of 8.8 (95 percent CI 5.8 to 11.7) and LR− of 0.52 (0.46 to 0.59). For a patient with a pretest probability for clinically significant CAD of 50 percent, an ECG suggesting ischemia would yield a posttest probability of 90 percent. An ECG without evidence of ischemia would yield a posttest probability of 34 percent. The 12-lead ECG had a higher LR+ (a positive test increases the likelihood of disease), but the PRIME ECG had a lower LR− (a negative test lowers the likelihood of disease). However, neither of these differences was statistically significant as judged by the overlapping confidence intervals, nor were they clinically significant as judged by the similar posttest probabilities.

Table 5 PRIME ECG^*^ performance characteristics

Author | Sample size | Sensitivity | Specificity | Likelihood ratio positive | Likelihood ratio negative
Menown et al., 1998^36^ | 314 | 76.9% | 85.1% | 5.2 | 0.27
Menown et al., 2001^37^ | 24 | 87.5% | 75.0% | 3.5 | 0.17
McClelland et al., 2003^38^ | 103 | 64.2% | 94.0% | 10.7 | 0.38
Navarro et al., 2003^39^ | 379 | 62.0% | 79.8% | 3.1 | 0.48
Owens et al., 2004^40^ | 294 | 80.2% | 92.0% | 10.0 | 0.22
Owens et al., 2008^41^ | 755 | 76.0% | 92.0% | 9.5 | 0.26
Summary (95% CI) | 1869 | 68% (63 to 74%) | 86% (83 to 90%) | 5.0 (3.5 to 6.5) | 0.37 (0.30 to 0.43)
Summary (95% CI; omits Menown et al., 1998^36^ and Menown et al., 2001^37^) | 1531 | 70% (66 to 75%) | 89% (86 to 93%) | 6.5 (4.2 to 8.8) | 0.33 (0.28 to 0.39)

* PRIME ECG (FDA cleared; commercially available; initially Meridian Medical Technologies, Belfast – now owned by Heartscape Technologies, Columbia MD).

Abbreviations: CI = confidence interval; ECG = electrocardiogram.

Table 6 12-lead ECG performance characteristics

Author | Sample size | Sensitivity | Specificity | Likelihood ratio positive | Likelihood ratio negative
Menown^*^ et al., 2001^37^ | 24 | 50% | 88% | 4.0 | 0.57
McClelland et al., 2003^38^ | 103 | 45.3% | 94.0% | 7.6 | 0.58
Navarro et al., 2003^39^ | 379 | 54.4% | 97.1% | 18.9 | 0.47
Owens et al., 2004^40^ | 294 | 57.1% | 93.8% | 9.1 | 0.46
Owens et al., 2008^41^ | 517 | 81.8% | 92.0% | 5.6 | 0.60
Summary (95% CI) | 1555 | 61% (46 to 76%) | 94% (92 to 96%) | 8.8 (5.8 to 11.7) | 0.52 (0.46 to 0.59)

* Not included in meta-analysis due to small sample size.

Abbreviations: CI = confidence interval; ECG = electrocardiogram.

All studies used myocardial injury as the reference standard and included subjects with ischemic type chest pain. Patients with ischemic type chest pain certainly form an important subgroup of the target population, but patients at lower risk for CAD (such as individuals with atypical chest pain) were not included. Applicability was also limited by the reference standard. Myocardial injury is an important outcome of interest, but clinicians are also concerned with identifying significant CAD that may affect functional status or survival prior to myocardial injury.

Studies meeting expanded eligibility criteria with FDA cleared devices. For the FDA-cleared 3DMP, no studies met our full inclusion criteria, but we identified four studies that met our expanded inclusion criteria (Table 7). These four studies included subjects scheduled for coronary angiography for any indication; one enrolled subjects with a history of coronary revascularization.35 The clinical symptoms (e.g., presence of chest pain), prior evaluation, and clinical risk score were not reported, making the clinical risk category and applicability to our population of interest uncertain; the prevalence of coronary artery disease by angiography ranged from 32 to 57 percent. These four studies included 920 subjects who were evaluated using 3DMP, and one study also evaluated the resting 12-lead ECG. Two studies were conducted in Germany, one in Southeast Asia, and one in the United States. All studies used a threshold of 4.0 on the 0 to 20 severity score to define an abnormal 3DMP test result.

Table 7 Studies evaluating performance characteristics of the 3DMP^*^

Study | Subjects | Setting | Threshold | Reference | Outcomes
Weiss et al., 2002^42^ | Ambulatory patients scheduled for CA (n = 136); 81 male, 55 female | Westchester Medical Center | Manual and automated analyses – 6 indices integrated and compared to results from a 21,000 patient database | Cardiac angiography: > 60% obstruction in a coronary artery | Severity Score: = 4.0 Sensitivity = 93.3% (76/78) Specificity = 83% (40/58)
Grube et al., 2007^34^ | Outpatients scheduled for CA – any indication (n = 423); mean age 61.4 (11.1); 258 men, 165 women | German Heart Center | Automatic differential diagnosis based on indices of abnormality; severity score 0–20 | Cardiac angiography: = 50% obstruction in left main or > 70% obstruction in any other coronary artery | Severity Score: = 4.0 Sensitivity = 89% (179/201) Specificity = 81.1% (180/222) aROC = 0.843
Grube et al., 2008^35^ | History of prior coronary revascularization procedure, scheduled for CA (n = 172); mean age 63.9 (10);116 men, 56 women | German Heart Center | Automatic differential diagnosis based on indices of abnormality; severity score 0–20 | Cardiac angiography: = 50% obstruction in left main or > 70% obstruction in any other coronary artery | Severity Score: = 4.0 Sensitivity = 90.9% (50/55) Specificity = 88.0% (103/117)
Hosokawa et al., 2008^43^ | Scheduled for CA (n = 189); mean age 61.3 (12.9); 132 male, 57 female | Cardiac catheterization lab – 5 southeast Asian countries | Automatic differential diagnosis based on indices of abnormality; severity score 0–20 | Cardiac angiography: = 50% obstruction in left main or > 70% obstruction in any other coronary artery | Severity Score: = 4.0 Sensitivity = 94.8% (73/77) Specificity = 86.6% (97/112) aROC = 0.914 (0.868 to 0.961)

* 3DMP = Multifunction Cardiogram^sm^ (FDA cleared, commercially available, Premier Heart, LLC, Port Washington, NY).

Abbreviations: aROC=area under the receiver operator curve; CA=coronary angiography.

We used a bivariate random-effects model to combine results across studies (Table 8). Studies were statistically heterogeneous for LR+ (Q = 7.6, df = 3, p = 0.06; I^2^ = 60 percent), but not for LR− (Q = 5.2, df = 3, p = 0.16; I^2^ = 42 percent). The heterogeneity could not be explained by differences in study design. The summary estimate for the LR+ was 5.3 (95 percent CI 3.8 to 6.9) and for the LR− was 0.09 (0.04 to 0.13). For a patient with a pretest probability for clinically significant CAD of 50 percent, a 3DMP score of 4 would yield a posttest probability of 84 percent. A 3DMP score < 4 would yield a posttest probability of 8 percent. The single study that evaluated the 3DMP and 12-lead ECG42 found a higher sensitivity (97 percent, 95 percent CI 94 to100 versus 75 percent, 65 to 85) and specificity (72 percent, 61 to 84 versus 41 percent, 28 to 54) for the 3DMP. However, this study had important methodological limitations. Of 200 patients selected for study, 64 were excluded due to inadequate 3DMP tracings, and criteria for an ECG diagnosis of CAD were not specifically stated. Since there were differences in the subjects and reference standard, these results are not directly comparable to the PRIME ECG or to the 12-lead ECG results discussed above. Although these results show impressive discriminate validity, it is uncertain how the device would perform in outpatients with undifferentiated chest pain that would certainly include more individuals with mild disease (potentially lowering sensitivity) or in patients with body habitus or comorbid diseases that may decrease accuracy.

Table 8 3DMP^*^ performance characteristics

Author | Sample size | Sensitivity | Specificity | Likelihood ratio positive | Likelihood ratio negative
Weiss et al., 2002^42^ | 136 | 97.4% | 72.4% | 3.5 | 0.04
Grube et al., 2007^34^ | 423 | 89.1% | 81.1% | 4.7 | 0.13
Grube et al., 2008^35^ | 172 | 90.9% | 88.0% | 7.6 | 0.10
Hosokawa et al., 2008^43^ | 189 | 94.8% | 86.6% | 7.08 | 0.06
Summary estimate (95% CI) | | 92.9% (88.7 to 97.2%) | 82.1% (75.7% to 88.4%) | 5.3 (3.8 to 6.9) | 0.09 (0.04 to 0.13)

* 3DMP = Multifunction Cardiogram^sm^ (FDA cleared, commercially available, Premier Heart, LLC, Port Washington, NY).

Abbreviation: CI = confidence interval.

### Key Question 2c What is the evidence that ECG-based signal analysis technologies impact diagnostic decisionmaking?

Our search strategy did not identify any eligible studies pertinent to this question.

### Key Question 2d What is the evidence that ECG-based signal analysis technologies impact patient outcomes?

A single, multicenter observational study evaluating the effects of the PRIME ECG on clinical outcomes was published after our search date but identified during peer review.44 The study tested the hypothesis that individuals with ST elevation myocardial infarction (STEMI) detected only by the PRIME ECG would have similar angiographic pathology and similar mortality and morbidity rates to those with STEMI detected by standard ECG. Adults (n = 1830) presenting to 12 tertiary care emergency departments with chest pain or symptoms suspicious for acute coronary syndrome who were at moderate to high risk for adverse cardiovascular outcomes were enrolled. Based on the study population, the study met our expanded eligibility criteria and indirectly addresses effects on patient outcomes. Subjects underwent testing with a standard 12-lead ECG and the PRIME ECG, but logistical difficulties prevented a substantial number of subjects with STEMI on standard ECG from completing the PRIME ECG, thus direct comparisons were not possible. Both the PRIME ECG and standard ECG were interpreted by experts. Clinical outcomes were compared between those with STEMI by standard ECG versus those with STEMI detected only by PRIME ECG and included 30-day mortality, myocardial infarction, and rehospitalization. In effect, these analyses evaluated the value of the PRIME ECG used as an “add-on” test to the standard ECG in emergency department patients with symptoms of acute coronary syndrome.

Of the 1830 subjects enrolled, 91 (4.97 percent) had STEMI by standard ECG. Of the remaining 1736 patients, 25 had STEMI by PRIME ECG. Therefore a diagnostic strategy that used the PRIME ECG as an add-on test would detect a total of 116 subjects with STEMI (6.34 percent) versus 91 by standard ECG alone (4.97 percent), for an incremental gain of 1.43 percent more patients detected with STEMI. A subset of those with PRIME ECG STEMI (n = 14) underwent coronary angiography that showed similar anatomy to those with STEMI by standard ECG. Clinical outcomes at 30 days did not differ significantly between those with STEMI by standard versus PRIME ECG only, but sample sizes were small, and the study was not powered to detect a clinically significant difference. These results provide preliminary data that the PRIME ECG can detect a small subset of patients without STEMI by standard ECG who have angiographic and clinical outcomes that are similar to individuals with STEMI by standard ECG. A more robust design would directly compare differences in diagnostic and treatment decisionmaking (e.g., decision to admit to hospital or proceed to emergent catheterization) and clinical outcomes.

### Summary

In summary, only the PRIME ECG has been evaluated in patients with acute chest pain, but it was compared to an incomplete reference standard. The reference standard used (biomarkers) detects only acute myocardial injury. This is less than ideal, since clinicians are also concerned with identifying significant CAD that may affect functional status or survival prior to myocardial injury. Although the PRIME ECG had a better LR− than the standard 12-lead ECG, the differences were not large and are unlikely to affect current diagnostic strategies. The 3DMP has not been evaluated in the population of interest, but its reliability and test performance in subjects at high risk or with known CAD is promising. Other devices identified are either not commercially available or not FDA cleared, and there is little published literature describing their performance. The literature is not sufficient to determine if factors such as sex, body habitus, medications, and comorbid medical conditions affect test performance. Finally, we did not identify any studies evaluating the effects of these tests on clinical decisionmaking or patient outcomes. To fully assess the impact of these devices on the diagnostic strategies for patients with chest pain, test performance needs to be linked to clinically important outcomes through modeling or longitudinal studies, potentially including randomized trials.