# Methods

## Key Questions

The sponsor of this report, AHRQ, identified two key questions to be addressed. The Duke Evidence-based Practice Center (EPC) research team further clarified these questions and research objectives through consultation with the AHRQ Task Order Officer assigned to the project.

At the most general level, the objectives of this report are to: (1) identify and describe devices and methods for ECG-based signal analysis that are being used, or are proposed to be used, for the diagnosis of CAD; and (2) summarize the available clinical and scientific evidence on the use of ECG-based signal analysis technologies for the diagnosis of suspected CAD in the ambulatory setting under nonprovocative conditions. These questions can be further broken down as follows:

- Key Question 1:
  a. What devices and methods for ECG-based signal analysis are being used or are proposed to be used for diagnosis of CAD? What is the FDA status of these devices?
  b. What are considered the “gold standard” tests for the diagnosis of CAD and what are their strengths and limitations?
- Key Question 2:
  a. What is the evidence for inter-rater, intra-rater, intra-patient, and intra-device variability?
  b. What is the evidence for diagnostic test performance compared to the reference standard used in the study? What factors (confounders) affected test sensitivity and specificity?
  c. What is the evidence that ECG-based signal analysis technologies impact diagnostic decisionmaking?
  d. What is the evidence that ECG-based signal analysis technologies impact patient outcomes?

## Analytic Framework

We developed an analytic framework based on principles from Fryback and Thornbury’s hierarchical model of diagnostic efficacy.9 This framework proposes a multilevel evaluation of diagnostic tests, beginning with studies of reliability, progressing through diagnostic test performance, and ending with the effects on relevant patient outcomes. This analytic framework (Figure 2) guided our research questions, search strategy, data abstraction elements, and evaluations.

Figure 2 Analytic framework

Figure 2 is a line, box, and circle type of diagram depicting the conceptual or analytic model for key decision points in testing strategies for patients with possible coronary artery disease. At the left is a circle representing a given population. Arrows are used to indicate movement of a given individual through testing strategies. Diagnostic tests or procedures may be administered, of which signal-averaging ECG may be one. A decision threshold is then met whereby a decision is made to categorize a given patient into one of three categories: (1) low likelihood of coronary artery disease; (2) high likelihood of coronary artery disease; and (3) further testing indicated. Depending on which category a person is in, different testing or treatment strategies may be employed.

## Approach

### Sources of Information and Review Methods

The sources of information consulted, as well as the review methods used by the Duke team, varied according to the key question being addressed. For Key Question 1, we conducted a comprehensive review of literature and gathered and collated information from the FDA, device manufacturers, and other relevant sources. Key Question 1 also involved summarizing information about commonly used diagnostic tests, procedures, and strategies. Both Key Question 1 and Key Question 2 required similar systematic literature search strategies, but the data extracted from the eligible studies were quite different; the purpose of the literature search for Key Question 1 was to identify potentially eligible devices or methods, while the purpose of the literature search for Question 2 was to synthesize the available scientific evidence that pertains to ECG-based signal analysis technologies that may potentially be applicable to the diagnosis of CAD in a patient without known CAD, but who presents with chest pain.

### General Approach

We conducted a systematic search of the English-language literature indexed in PubMed^®^ and a search of the U.S. Food and Drug Administration (FDA) web site, Google™, and online patents. We sought to identify devices that improved CAD diagnosis through their use of signal analysis, spectral analysis, or other forms of advanced data transformation. We specifically excluded devices that used imaging techniques such as echocardiography or coronary angiography. We identified the major categories of electrocardiography, including body surface mapping potential, phonocardiography, and magnetocardiography.

After discussions with our stakeholders, we narrowed our focus to devices that: (1) obtain and interpret information about the heart’s electrical activity; (2) interpret the electrical signal in a novel way using advanced mathematics (e.g., fast Fourier transform or spatial imaging); and (3) interpret specifically for the purpose of diagnosing CAD or myocardial ischemia. We used the above-stated criteria to define ECG-based signal analysis devices for the purpose of this report.

We limited our search to named devices for which we could identify a manufacturer or distributor. We reviewed all of the studies identified that reported on any device or method that met the above-stated criteria. We excluded from formal analysis those devices for which we could not find evidence of commercial availability.

### Literature Sources and Search Strategies

We devised three main strategies for gathering information. First, we searched PubMed from January 1949 to May 2009 using search terms for the specific devices identified in the horizon scan, terms for signal analysis or spectral analysis, and terms for CAD or myocardial ischemia. For studies of reliability, we added terms related to precision, test-retest reliability, and inter- or intrarater reliability. The exact search strategies used are detailed in Appendix A. The titles and abstracts of all citations retrieved through searches of PubMed were screened by two reviewers for potential inclusion. All citations that appeared to report primary data relevant to the study question were retrieved for full-text review.

Second, we conducted an extensive search of the “gray literature” on this subject. A single investigator searched each of the general gray literature sources listed in Appendix B, including the ClinicalTrials.gov web site (www.clinicaltrials.gov), in order to identify potentially relevant devices. We were assisted in this effort by a representative of the FDA and a Duke University Medical Center librarian with expertise in gray literature searching, who suggested sources and search terms.

Finally, we contacted Drs. Mark Donahue and Mitchell Krucoff (both of Duke University Medical Center), who are experts in the field of ECG technologies, to ask if they were aware of any additional devices that should be included in our review.

### Inclusion and Exclusion Screening Criteria

Titles and abstracts were screened for eligibility by two investigators and selected for full-text review if either investigator deemed the study potentially eligible. Eligibility criteria were specific to each question and are detailed in Appendix C. General eligibility criteria included:

- Relevant device.
- Tested in outpatients at low to intermediate risk for CAD.
- Relevant outcomes reported, including performance characteristics, effects on diagnostic or treatment decisions, or effects on patient outcomes.
- N > 30.

Since few studies met eligibility criteria, we broadened the criteria to include studies evaluating individuals at higher risk for CAD (such as inpatients or those scheduled for cardiac catheterizations). These expanded eligibility criteria were applied to questions 2b–2d. Although these studies may have had poor applicability to the target population, they provided some relevant information.

### Data Abstraction

For eligible studies, an investigator abstracted data into an evidence table and assigned quality ratings. Abstracted data included first author, year of publication, study design, patient selection criteria and patient characteristics, information about the study device, reference tests used, device and reference test performance characteristics, and quality assessment ratings. A second investigator overread abstracted data and independently assigned quality ratings. Disagreements were resolved by consensus. Quality ratings were based on the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) instrument10–12 and included characteristics of sample selection, adequate description of the index and reference tests, blinded interpretation of the index and reference tests, presence of incorporation and verification bias, and an assessment of the analysis approach appropriateness (Appendix D). Appendix E presents summary evidence tables for all included studies. Appendix F provides details of the reviewers’ assessment of quality for each eligible study.

Device performance was summarized using sensitivity, specificity, and likelihood ratios. A test’s sensitivity describes the proportion of subjects with disease who have an abnormal test. Test specificity describes the proportion of subjects without disease who have a normal test. A likelihood ratio is a measure that may be more useful to clinicians since a simple nomogram allows posttest disease probabilities to be calculated readily. The likelihood ratio positive (LR+) describes how many times more likely it is that an abnormal test comes from a patient with disease versus a patient without disease. The likelihood ratio negative (LR−) describes how many times more likely it is that a normal test comes from a patient with disease versus a patient without disease.

When studies were conceptually homogeneous, we used random-effects bivariate meta-analysis to compute a summary estimate of performance.13 For studies that derived a test algorithm in a training set and tested performance in a validation sample, we analyzed performance characteristics from the validation set. We evaluated statistical heterogeneity by inspecting forest plots and computing Q and I^2^ statistics. Since the Q test is underpowered, we set the threshold for significant heterogeneity at p < 0.10. For the I^2^ test, a suggested interpretation is to assign the terms low, moderate, and high to I^2^ values of 25 percent, 50 percent, and 75 percent, respectively.14

### Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the project to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include three progressively stricter screening opportunities for each article (abstract screening, full-text screening, and data abstraction); involvement of at least two individuals (an abstractor and an over-reader) in each data abstraction; and agreement of at least two clinicians on all included studies.

Our principle external quality-monitoring device was the peer-review process. Nominations for peer reviewers were solicited from several sources, including clinical content experts from the Duke Research Team and the AHRQ. The list of nominees was forwarded to the AHRQ for vetting and approval.