# Introduction

## Epidemiology of Coronary Artery Disease (CAD)

Cardiovascular disease remains the leading cause of mortality in the United States. An estimated one in three adults has one or more types of cardiovascular diseases, including hypertension, coronary artery disease (CAD), heart failure, stroke, and congenital defects.1 Approximately 13 million patients have CAD. Of these individuals, approximately seven million have angina pectoris (chest pain) and have had a myocardial infarction.1 While chest pain is a common symptom of patients presenting to clinics and emergency wards, only about six percent of patients presenting to the emergency room with acute chest pain are ultimately diagnosed with myocardial infarction.2 Identification of which patients with chest pain are experiencing myocardial ischemia or infarction is critical since a delay in diagnosis can impede the application of effective therapies, such as thrombolytic agents or primary percutaneous coronary intervention (PCI). Tests that identify patients with significant CAD serve as a means of facilitating aggressive implementation of secondary preventive strategies. In a large national sample, only 37.6 percent of patients without known CAD referred for elective coronary angiography, most of whom had undergone prior noninvasive testing, were found to have obstructive CAD.3 Thus, accurate noninvasive diagnostic tests and protocols are significantly important in order to properly triage patients presenting with chest pain, and currently available tests identify a relatively low proportion who will benefit from secondary prevention.

## CAD vs. Ischemia vs. Infarct

A diagnosis of CAD results from the findings suggestive of atherosclerotic plaque within the coronary arteries. This plaque may or may not represent an obstruction to coronary blood flow. The build-up of atherosclerotic plaque is a progressive and diffuse process that develops within the coronary arteries. Plaque formation may begin prior to middle age, as evidenced from previous autopsy studies of young soldiers and young victims of motor vehicle accidents. CAD is believed to have a polygenetic basis, influenced by an individual’s genes, as well as their susceptibility to environmental influences (such as diet and exercise). The progression and severity of CAD is associated with advancing age, such that older individuals have a higher likelihood of having CAD, even without the presence of other risk factors.

Patients with CAD may or may not present objective evidence of myocardial ischemia (defined as a mismatch between coronary blood flow and myocardial oxygen demand). Traditional observations have indicated that myocardial ischemic imbalance may begin to occur when the luminal narrowing of the coronary artery exceeds 70 percent. In a clinical setting, ischemia may trigger an episode of angina pectoris or other equivalent symptoms of reduced oxygen delivery to the myocardium (e.g., shortness of breath, epigastric discomfort, jaw or arm pain/heaviness). Stress tests (whether solely electrocardiographic or combined with imaging modalities), are designed to qualitatively or quantitatively identify decreased regional myocardial blood flow in the distribution of its corresponding coronary artery. Patients who exhibit demonstrable ischemia on stress testing and whose symptoms are not optimally managed with medical therapy are often referred for diagnostic angiography and elective revascularization.

Prolonged ischemia may result in myocardial infarction, although infarction can also develop in nonobstructive coronary vessels as a consequence of a spontaneous atheromatous plaque rupture. The hallmark of infarction is elevation of cardiac muscle biomarker serum levels, including cardiac troponin and the creatine kinase MB isoenzyme. Elevations of cardiac troponin serve as evidence of myocardial cell death. Compared to patients without a prior myocardial infarction, patients with a history of myocardial infarction are at higher risk for future cardiac events, including recurrent infarction and death.

## Diagnostic Testing and Risk Stratification for CAD

Patient history and physical examination are the starting points of a diagnostic workup for suspected CAD. Additional diagnostic testing may be indicated if such testing can support or modify (in a clinically meaningful manner) the clinician’s initial risk assessment of the patient, thereby helping to clarify the appropriate management strategy. Validated risk scores have been developed for a variety of clinical settings, including the emergency department and general medical setting.4

Figure 1 illustrates the relationship between risk stratification and clinical decisionmaking for patients without known CAD who present with chest pain or other symptoms for which CAD-related myocardial ischemia is a possible etiology. Tests designed to diagnose CAD may not be indicated in patients who are deemed to be at very low risk, such as in the case of a healthy 22-year-old woman with atypical chest pain and no known risk factors for CAD. Similarly, a 73-year-old man with diabetes, hypertension, and a long history of tobacco use who presents with exertional substernal chest pain is likely to be treated initially for presumptive myocardial ischemia without confirmatory testing for CAD. In neither scenario would diagnostic testing be expected to move a patient across decisionmaking thresholds (indicated by the letters A and B in Figure 1).

Figure 1 Decision threshold conceptual model

Figure 1 is a line type of diagram depicting a horizontal line that represents the spectrum of likelihood of any given person having coronary artery disease, with 0% likelihood at the extreme left, and 100% likelihood at the far right. Somewhere along that line lie point A, which represents a decision threshold between no further testing or treatment indicated and further testing possibly indicated, and point B, which represents a decision threshold between further testing possibly indicated and treatment indicated.

Noninvasive diagnostic testing may, however, be particularly informative for the large population of patients who are best categorized as having a low to intermediate risk for CAD, yet who present with chest pain or other symptoms suggestive of CAD. For this category of patients, noninvasive test results have proven to be useful for posttest decisionmaking.5 Within this framework of pretest risk prediction, decisions regarding which diagnostic test to use, or the decision not to perform a test at all, must be made.

## The Role and Limitations of the ECG in the Diagnostic Workup of CAD

In patients where CAD is suspected – either because of the presence of risk factors for CAD or because of symptoms that may represent manifestations of CAD (e.g., chest pain) – the standard ECG is one of the most commonly performed tests.6 By providing a “snapshot” of the heart’s electrocardiographic activity, the ECG allows the reader to assess the presence of myocardial infarct, ischemia, hypertrophy, or arrhythmia, as well as the risk of inherited cardiomyopathies such as long-QT syndrome or Wolff-Parkinson-White syndrome. The ECG is nearly universally available, and is noninvasive, easy to perform, relatively inexpensive, and expedient (an ECG can usually be performed in less than 10 minutes). In addition, most ECG machines are equipped with computerized diagnostic algorithms that provide an immediate preliminary interpretation, which is made available for physician over-read.

However, the ECG has several significant limitations. First, an ECG represents electrocardiographic activity at a single moment in time while the patient is at rest. This means that an ECG cannot provide information about a patient’s functional capacity. Moreover, ECGs often need to be repeated as a patient’s clinic condition changes. Second, wave pattern recognition and comparison to expected normal findings are used in ECG assessment, but the final analysis is open to subjective interpretation by the reading physician. Finally, a resting ECG’s diagnostic utility is limited, given that the test’s estimated sensitivity for the diagnosis of CAD is low (between 12 and 70 percent depending on the population studied and criteria applied).7,8

## Evaluating Emerging ECG-based Technologies

New devices that seek to improve ECG capabilities have been proposed – specifically, devices that are potentially capable of detecting significant CAD or myocardial ischemia. An enhanced ECG-based test might demonstrate greater positive or negative predictive values, thereby limiting the harms associated with delays in treatment (as in the example of a posterior myocardial infarction that was not evident on the 12-lead ECG), or by providing the diagnostic information necessary to avoid invasive diagnostic or therapeutic interventions.

Ideally, all new tests would be compared to the reference standard that most accurately discriminates between individuals with and without disease. Additionally, the relative advantages of a new test should be evaluated in comparison to existing technology. For example, in patients with low to intermediate risk of CAD who present with chest pain, an enhanced test might serve as a better initial diagnostic instrument. Enhanced ECG technology could be used instead of, or in addition to, the standard 12-lead ECG. Regardless of whether a new test is intended to complement or replace the standard ECG, the performance characteristics of both technologies should be evaluated relative to one or more appropriate reference standards.

## Objectives of this Report

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Duke Evidence-based Practice Center (Contract No. HHSA 290-2007-10066I). The purpose of the technology assessment is to summarize the available clinical and scientific evidence on ECG-based signal analysis technologies for evaluating patients with chest pain at low to intermediate risk for CAD. The report does not address the use of these technologies to screen asymptomatic individuals for CAD or focus narrowly on acute coronary syndrome that may present with symptoms other than chest pain. A horizon scan was performed to identify emerging technologies that noninvasively analyze electrical signals from the heart, which we have collectively termed “ECG-based signal analysis technologies. One form of signal analysis is the signal-averaged ECG which analyzes the ECG by computing the average of numerous ECG complexes. This increases the signal-to-noise ratio, allowing for the detection of small, microvolt signals. This technique is most often used in the detection of low amplitude signals at the terminal portion of the QRS complex (also known as ventricular late potentials). These late potentials may reflect inflammation, edema, fibrosis, or infarct. A newer form of ECG-based signal analysis utilizes mathematical modeling to derive clinical indices. These indices are then compared with an empirical database to generate differential diagnoses and a heart disease severity score. Another ECG-based signal analysis technology is body surface mapping (also called body surface potential mapping) which uses up to 120 ECG electrodes to expand the measured area of electrocardiographic activity. Data collected by these electrodes are used to construct a three-dimensional representation of the thorax. Some ECG-based signal analysis technologies have been used for purposes other than detecting CAD, but these uses are not the focus of the current report. For example, we specifically excluded the use of ECG-based signal analysis technologies for measuring heart rate variability since this is aimed at predicting malignant arrhythmias. This report concentrates on commercially available ECG-based signal analysis devices to inform AHRQ and the CMS about the utility of these emerging technologies for diagnosing CAD.