# Quality Assessment Ratings

| Menown et al., 1998^36^ | Menown et al., 2001^37^ | McClelland et al., 2003^38^ | Navarro et al., 2003^39^ | Owens et al., 2004^40^ | Owens et al., 2008^41^ | Solomon and Tracy, 1991^47^ | Weiss et al., 2002^42^ | Grube et al., 2007^34^ | Grube et al., 2008^35^ | Hosokawa et al., 2008^43^
Random/consecutive sample | No, controls from epidem study | Consecutive | Consecutive | Consecutive | Consecutive | Consecutive | Consecutive | No | Can’t tell | Can’t tell | Consecutive
Appropriate selection criteria | Partial; controls without CP and normal ECG | Partial, excluded those with BBB; all had ST depression | Yes | Yes | Yes | Yes | Partial, cath scheduled | Partial, cath scheduled | Partial, cath scheduled | No, recent revascularization | Partial, cath scheduled
Index test described | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Reference test described | No, Biomarker not specified | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Valid reference standard | No, Biomarkers not specified | Yes | Yes | No (single biomarker) | No (incomplete biomarkers) | No (uncertain biomarkers) | Yes | Yes | Yes | Yes | Yes
Blinded reference test | Can’t tell | Can’t tell | Can’t tell | Can’t tell | Yes | Can’t tell | Can’t tell | Yes | Yes | Yes | Yes
Blinded index test | Can’t tell | Can’t tell | Can’t tell | Can’t tell | Can’t tell | Yes | Can’t tell | Yes | Yes | Yes | Yes
No verification bias | No, not all had biomarkers | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
No incorporation bias | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Appropriate analysis | Yes, training & validation sets | Yes | Yes | Yes | Partial, no validation set | Partial, no validation set | Yes | No | Yes | Yes | Yes

Abbreviations: BBB = bundle branch block; cath = catheterization; CP = chest pain; ECG = electrocardiogram.