# Quality Criteria

## Sample or Study Design

- Random or consecutive sample?: yes, no, can’t tell
- Selection criteria favor representative spectrum of disease?: yes, no, can’t tell
  Yes = Individuals with comorbid conditions (e.g., COPD) or body habitus (e.g., obesity) that may affect index test result are not excluded. In patients with CAD, severity ranges from mild (e.g., single vessel disease) to severe (3 vessels or left main).

## Reference Test

- Index test adequately described?: yes, no
  Yes = Described in enough detail to replicate with confidence
- Reference test adequately described?: yes, no
  Yes = Described in enough detail to replicate with confidence; criteria for an abnormal result (e.g. CAD, myocardial ischemia) prospectively defined and clearly stated
- Is reference test a valid reference standard?: yes, partially, no
  See definitions from question 1a
- Reference test interpreted blinded to index test result?: yes, no, can’t tell
- Index test interpreted blinded to reference test result?: yes, no, can’t tell
- Absence of verification bias (independence of indication for tests)?: yes, no, can’t tell
  Yes = All subjects had both the index and reference test; the reference test applied was the same for index test positive and index test negative groups. Note – if eligibility criteria required that patients have both the index test and reference test, then – by definition – verification bias is absent. However, this eligibility reference makes it less likely that a random or consecutive sample was obtained.
- Absence of incorporation bias (definition of disease/abnormal by the reference standard does not include (incorporate) the index test result)?: yes, no

## Analysis

- Analysis appropriate?: yes, no, partially
  Consider: a) handling of intermediate or indeterminate data; b) a priori definition of abnormal result; and c) able to calculate sensitivity/specificity, likelihood ratios, diagnostic odds ratio, ROC curve, or c statistic

Other issues to consider but not part of formal quality rating – relevant to applicability

1. Patient population: age group (Medicare, = 65 y.o); do inclusion criteria select for outpatients with low to intermediate likelihood of CAD?
2. Intervention: a) Was the index test performed or interpreted by technicians/clinician with specialized training such that the index test is likely to perform better in their hands compared to technicians/clinicians in routine clinical care?; b) Is there any information given on the amount of time taken to administer and interpret the index test? – would have implications for real world practice?