# Inclusion/Exclusion Criteria

## Question 2a What is the evidence for inter-rater, intra-rater, intra-patient and intra-device variability?

- Patients: Adults with chest pain or being evaluated for myocardial ischemia/CAD
- Intervention: Commercial Device^*^ using ECG based technology on our list of included devices (e.g. evaluates electrical waveforms with advanced analytic techniques such as computer evaluation of vectors)
- Outcome: Reliability measure (e.g., simple agreement, kappa, intraclass correlation)
- Setting: Outpatient or inpatient
- Study Design: N>30

## Question 2b What is the evidence for diagnostic test performance compared to a criterion standard?

- Patients: Adults with chest pain, at low to intermediate risk for CAD, being evaluated for myocardial ischemia/CAD
- Intervention: Commercial Device using ECG based technology on our list of included devices (e.g. evaluates electrical waveforms with advanced analytic techniques such as computer evaluation of vectors)
- Outcome: Comparison to an acceptable reference standard^**^
- Setting: Outpatient (to include physician offices, urgent care and ED)
- Study Design: N>30

## Question 2c What is the evidence that signal-analysis technologies impact diagnostic decisionmaking?

- Patients: Adults with chest pain, at low to intermediate risk for CAD, being evaluated for myocardial ischemia/CAD
- Intervention: Commercial Device using ECG based technology on our list of included devices (e.g. evaluates electrical waveforms with advanced analytic techniques such as computer evaluation of vectors)
- Comparator: Comparison to an alternative diagnostic test (or test strategy)
- Outcome: Further diagnostic testing
- Setting: Outpatient (to include physician offices, urgent care and ED)
- Study Design: Cross-sectional, longitudinal observational or randomized controlled trial, N>30

## Question 2d What is the evidence that signal-analysis technologies impact patient outcomes?

- Patients: Adults with chest pain, at low to intermediate risk for CAD, being evaluated for myocardial ischemia/CAD
- Intervention: Commercial Device using ECG based technology on our list of included devices (e.g. evaluates electrical waveforms with advanced analytic techniques such as computer evaluation of vectors)
- Comparator: An alternative diagnostic test (or test strategy)
- Outcome: Clinical - mortality, cardiac symptoms or function, functional status; process - therapeutic interventions
- Setting: Outpatient (to include physician offices, urgent care and ED)
- Study Design: Longitudinal observational or randomized controlled trial, N>50

### Key features of relevant devices

- Obtains and interprets electrical activity from the heart (so ECG device)
- May utilize standard 12 lead information or have fewer (e.g., 3DMP/mfEMT) or additional leads (e.g., body surface mapping)
- Transforms/interprets the electrical signal in a novel way. Data transformation into spatial imaging, or through advanced mathematics (e.g., Fast Fourier Transform) to produce new indexes are relevant.
- Is claimed to be useful for diagnosing CAD or detecting myocardial ischemia
- Is a commercially available device
- Any other device meeting these criteria