# ECG-Based Signal Analysis Devices – Gray Literature Sources, Search Terms, and Results

Source | Search term(s) | Restrictions | Number of citations identified | Unique devices identified
General gray literature sources
Google Advanced Search (http://www.google.com/advanced_search?hl=en) | [(“ECG” OR “electrocardiogram” OR “EKG”) AND (“signal averaging” OR “signal averaged” OR “signal analysis” OR “spectral”)] OR “body surface mapping” | - In the title of the page; - Published between April 22, 2008, and May 28, 2009; - English language | 175 | Procardia 7 Procardia 8 Cardiag 112.2 Cardiag 128.1 CarDx
Federal Drug Administration Searched via: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMA/pma.cfm; and http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm | Product codes: DPS, LOS, DRW, KRC, MLO, MWJ, OEY, KXN | None | 592 | 0
Patents Searched via www.freepatentsonline.com | (“cardiac” AND “spectral”) AND (“electrocardiograph” OR “electrocardiogram”) | None Searched May 17, 2009 | 1591 | 0
| “body surface mapping” AND “ischemia” | | 10,265
Abstracts from scientific meetings
American Heart Association (AHA) scientific sessions website (http://scientificsessions.americanheart.org/portal/scientificsessions/ss) Abstract Archive Tool search portal (http://www.abstractsonline.com/arch/home.aspx?lookupkey=12345) | "cardiac spectral" or "body surface mapping" or "signal averaging" | Abstract Archive Tool searches across all AHA-sponsored scientific meetings through 2004 | 23 | 0
Online search of the AHA’s journal Circulation (advanced search page: http://circ.ahajournals.org/search.dtl) | “signal analysis” or “signal averaged” or “signal averaging” or “body surface map” or “body surface mapping” | - In title or abstract; - Include AHA Scientific Sessions Abstracts; - July 2007 – June 2009 | 20 | 0
American College of Cardiology (ACC; http://www.acc.org/) Search page: http://content.onlinejacc.org/search.dtl | “signal averaging” or “signal averaged” or “surface mapping” or “body surface map” | - In title or abstract; - All JACC journals; - July 2007 – June 2009 | 9 | 0
Heart Rhythm Society (http://www.hrsonline.org/Sessions/) Search page: http://www.abstracts2view.com/hrs/ | All of the words: electrocardiogram AND signal averaging or signal averaged AND spectral analysis or body surface mapping | All abstract categories 2009–2009 | 5 | XL-ECG, Mortara Prime ECG
European Society of Cardiology (ESC; http://www.escardio.org/Pages/index.aspx) Search page: http://spo.escardio.org/abstract-book/topic.aspx | All of the words: electrocardiography, noninvasive studies, ECG and arrhythmia analysis, exercise testing in CAD, “signal”, “body” | 2007 and 2008 | 239 | 0
Ongoing trials
ClinicalTrials.gov (http://www.clinicaltrials.gov/) Basic Search: http://www.clinicaltrials.gov/ct2/search | “ischemia” AND (“electrocardiograph” OR “electrocardiogram”) | None Searched May 17, 2009 | 52 | 0