# PubMed® Search Strategies

Search Used for Question 1a and Questions 2b–d

1 | ("Signal Processing, Computer-Assisted"[Mesh] OR "signal averaged" OR "signal averaging" OR "signal analysis" OR "signal processing" OR "signal interpretation" OR "spectral analysis" OR “body surface potential mapping”)) | 39884
2 | (“Prime ECG” OR “PRIMEECG” OR “PRIME ECG” OR “3DMP/mfEMT OR “3DMP*” OR “multifunction-cardiogram” OR “multifunction cardiogram” OR “CARDx” OR “Arrhythmia research technology” OR “1200EPX” OR “fukuda denshi” OR “fdx-6521” OR “fdx 6521” OR “vcm-3000” OR “vcm 3000” OR “visual ecg”) | 44
3 | #1 OR #2 | 39902
4 | (ecg OR ekg OR electrocardiogram OR electrocardiography) | 174569
5 | ("coronary artery disease"[MeSH Terms] OR "coronary artery disease"[All Fields]) | 58288
6 | “myocardial ischemia”[MeSH Terms] OR “myocardial ischemia”[MeSH Terms] OR (“myocardial”[All Fields] AND “ischemia”[All Fields]) OR “myocardial ischemia”[All Fields] | 299759
7 | #5 OR #6 | 311377
8 | #3 AND #4 AND #7 | 1792
9 | #8 Limits: Limits: Human, English | 1361
10 | #8 Limits: Review | 188
11 | #9 NOT #8 | 1239

Search Used for Question 2a

1 | ("Signal Processing, Computer-Assisted"[Mesh] OR "signal averaged" OR "signal averaging" OR "signal analysis" OR "signal processing" OR "signal interpretation" OR "spectral analysis" OR “body surface potential mapping”) | 39884
2 | (“Prime ECG” OR “PRIMEECG” OR “PRIME ECG” OR “3DMP/mfEMT OR “3DMP*” OR “multifunction-cardiogram” OR “multifunction cardiogram” OR “CARDx” OR “Arrhythmia research technology” OR “1200EPX” OR “fukuda denshi” OR “fdx-6521” OR “fdx 6521” OR “vcm-3000” OR “vcm 3000” OR “visual ecg”) | 44
3 | #1 OR #2 | 39902
4 | (ecg OR ekg OR electrocardiogram OR electrocardiography) | 174569
5 | (((("Observer Variation"[Mesh] OR "Reproducibility of Results"[Mesh]) OR "Validation Studies "[Publication Type]) OR "Validation Studies as Topic"[Mesh]) OR (inter-rater OR intra-rater OR intra-patient OR intra-device OR validity OR relia* OR reproducib*)) | 478616
6 | ("coronary artery disease"[MeSH Terms] OR "coronary artery disease"[All Fields]) | 58288
7 | “myocardial ischemia”[MeSH Terms) OR “myocardial ischemia”[MeSH Terms] OR (“myocardial”[All Fields] AND “ischemia”[All Fields]) OR “myocardial ischemia”[All Fields] | 299759
8 | #6 OR #7 | 311377
9 | #3 AND #4 AND #5 AND #8 | 168
10 | #6 Limits: Human, English | 134