# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BSM: Body surface mapping
CA: Coronary angiography
CAD: Coronary artery disease
CCT: Cardiac computed tomography
CCU: Coronary care units
CK-MB: Creatine kinase, MB fraction
CMS: Centers for Medicare and Medicaid Services
COPD: Chronic obstructive pulmonary disease
CP: Chest pain
ECG: Electrocardiogram
EPC: Evidence-based Practice Center
ETT: Exercise treadmill test
FDA: U.S. Food and Drug Administration
LR−: Likelihood ratio negative
LR+: Likelihood ratio positive
MI: Myocardial infarction
PCI: Percutaneous coronary intervention
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
RCT: Randomized controlled trial
ROC: Receiver operator curve
SAECG: Signal averaging electrocardiogram
STEMI: ST elevation myocardial infarction
WHO: World Health Organization