# Results

Figure 3 shows the flow of literature through the literature search and screening process for Key Question 2 (literature search not applicable to Key Question 1). Of the 2000 citations identified by our database searches, 11 were duplicates. After applying inclusion and exclusion criteria at the title-and-abstract level, 295 full-text articles were retrieved and screened. Of these, 281 were excluded at the full-text screening stage, with 14 articles (representing 11 unique studies) remaining for data abstraction.

Figure 3 Literature flow diagram for Key Question 2

Abbreviations: ACs=acute coronary syndrome; CAD=coronary artery disease; KQ=key question

Figure 3 shows the flow of literature through the literature search and screening process for Key Question 2 (literature search not applicable to Key Question 1). Of the 2000 citations identified by our searches, 11 were duplicates. After applying inclusion/exclusion criteria at the title-and-abstract level, 295 full-text articles were retrieved and screened. Of these, 281 were excluded at the full-text screening stage, with 14 articles (representing 11 studies) remaining for data abstraction.

## Analysis for KQ 1

### KQ 1a Devices and Methods for ECG-based Signal Analysis

The gray literature search identified seven potentially relevant devices. We subsequently identified one additional device (the LP 3000 system) through our search of the published literature. These eight potentially relevant devices, all of which are available for purchase in the United States, are listed in Table 1. A device may be cleared for marketing by the FDA when it is determined to be substantially similar to an established device. Of the devices listed in Table 1, 8 have been cleared for marketing by the FDA: Predictor^®^ and Model 1200 EPX™ by Arrhythmia Research Technology; MAC^®^ 5000 by GE Medical; LP 3000 by Fidelity Medical; the PRIME ECG^®^ by Heartscape Technologies; 3DMP™/MCG™/mfEMT™ by Premier Heart; CardioSoft^®^ by NASA; and HyperQ™ by Biological Signal Processing. We identified several published articles that evaluated the test performance of the 3DMP and the Predictor; however, these studies are not included in this report because the devices were not administered to patients at low to intermediate risk being evaluated for ACS.

Table 1 ECG-based signal analysis devices identified by the gray literature search

Device Name | Manufacturer | FDA Cleared | Device Type
Predictor | Corazonix (now Arrhythmia Research Technology) | Yes | SA
Model 1200 EPX | Arrhythmia Research Technology | Yes | SA
MAC 5000 | GE Medical | Yes | SA
LP 3000 | Fidelity Medical | Yes | SA
PRIME ECG | Heartscape | Yes | BSM
3DMP/MCG/mfEMT | Premier Heart | Yes | MA
CardioSoft | NASA | Yes | HF-QRS
HyperQ (stress ECG) | Biological Signal Processing | Yes | HF-QRS

Abbreviations: BSM=body surface mapping; ECG=electrocardiogram; FDA=U.S. Food and Drug Administration; HF-QRS=high-frequency QRS; MA=mathematical analysis; SA=signal averaging

#### Body Surface Mapping Devices

Electrocardiographic BSM is an electrocardiographic technique that uses multiple electrocardiography leads (generally 80 or more) to detect cardiac electrical activity.17 An example of a commercially available BSM device is the PRIME ECG, which uses a disposable vest that incorporates additional electrodes to measure electrocardiac activity from the front, back, and sides of the torso to create an “80-lead ECG.” ECG recordings showing ST segment elevation—suggestive of acute myocardial injury—are represented on a torso map to localize and demonstrate the extent of injury. Areas on the torso map corresponding to regions of myocardium demonstrating ST segment elevation are color-coded red. Areas of ST depression are blue, and neutral areas are green. This colorimetric torso images are intended to help a health care provider rapidly scan the heart for significant abnormalities. A potential disadvantage of recording and analyzing data from many points on the body, however, is that this requires accurate interpretation of additional information. Some of this additional information may be useful (the “signal”), but some may be uninterpretable or unhelpful (“noise”).

#### Mathematical Analysis and Signal Averaging Devices

A variety of devices have been developed that use mathematical modeling to derive clinical indices from electrocardiac activity detected by a standard ECG. For example, the 3DMP device utilizes ECG data from 2 of the 12 standard leads (leads II and V5) to perform frequency and time-domain analyses. Recordings for more than 82 seconds are amplified, digitized, encrypted, and sent securely over the Internet to Premier Heart Datacenter, where signal analysis and mathematical transformations are performed to derive indices that in particular patterns may signify the presence of disease. The data are compared to a large empirical database to determine a “final diagnosis” and “severity score”; these are then securely reported back over the Internet within several minutes to the requesting provider.

Another example of a device that uses mathematical analysis is the LP 3000 system, which derives standard X, Y, and Z leads from a 12-lead ECG at 2 different time points. Signals are amplified, averaged, and filtered with a bidirectional filter at frequencies of 40 to 250 Hz. The filtered leads are then combined into a vector magnitude. The magnitude of the difference in filtered QRS duration—between a recording obtained when a patient is symptomatic and when a patient is asymptomatic—is used to identify patients who appear to demonstrate a significant alteration in QRS duration, and who are therefore at high risk for ischemic heart disease.18,19

#### High Frequency QRS Devices

The standard 12-lead ECG waveforms are typically measured in the frequency range up to 100 Hz. High frequency QRS (HF-QRS) electrocardiography uses a higher sampling rate, signal averaging, and filters to monitor frequencies from 150–250 Hz.20 Examples of HF-QRS devices are the CardioSoft and the HyperQ.

#### Vectorcardiography

Vectorcardiography typically uses four or five electrodes to measure the direction and magnitude of the electrical field vector of the heart. In vectorcardiography, data recorded from surface leads on the body generate three mathematically weighted orthogonal tracings: X, Y, and Z. These in turn provide three-dimensional information on voltage and special orientation of the summation vector of the surface potential that does not require a qualitative evaluation by an expert and which allows spatial analysis of beat-to-beat variability.21

### KQ 1b Gold Standard Tests

#### Tests for Diagnosing CAD

Diagnostic tests for CAD can be categorized as either invasive (e.g., coronary angiography via cardiac catheterization) or noninvasive. Noninvasive tests utilize technologies that permit either visualization of the heart and corresponding vasculature or interpretation of electrical signals generated by a beating heart. Coronary angiography can be used to detect the presence of CAD by identifying coronary artery occlusion, while noninvasive tests are used to infer the presence of CAD or ischemic heart disease by irregular electrical signals, abnormal heart wall motion, or damage to myocardial cells. Coronary angiography is universally accepted as diagnostic of clinically significant CAD.

Our discussion emphasizes the options for reference standards that might be considered in research studies to evaluate a new technology to aid in the diagnosis and management of patients suspected of having clinically significant CAD and/or ischemic heart disease.

##### Invasive Testing

Coronary angiography. Invasive coronary angiography involves the insertion and manipulation of slender catheter tubes from a percutaneously accessed arterial site (most commonly via the femoral artery) to the origin of the coronary arteries. Iodinated contrast agents are injected through these tubes, lighting up the arterial structure, and allowing x-ray images to be obtained. These images are then used in determining a diagnosis of and/or treatment for CAD. The cineangiograms are the recorded real-time x-ray images of the epicardial coronary arteries. These images are subsequently reviewed by the physician to determine the optimal management strategy for the patient. Lesions that obstruct 70 percent or more of the coronary lumen significantly restrict coronary blood flow and may cause functional obstruction (e.g., angina or angina-like symptoms). The traditional cutpoint of 70 percent obstruction is often accepted as the threshold for significant CAD and may prompt revascularization. Nevertheless, data challenging qualitative angiographic grading for revascularization on patient outcomes have recently been reported.22

Strengths and limitations of coronary angiography. The current role of coronary angiography has been to aid in the identification of patients who will benefit clinically from revascularization.23–27 Coronary angiography can be used in conjunction with contrast ventriculography to determine left ventricular function. According to a consensus guideline from the ACC/AHA, coronary angiography is the preferred reference standard for diagnosing the severity of obstruction in the coronary arteries since noninvasive testing currently lacks the sensitivity to exclude left main or multivessel CAD, which are independently associated with poor survival.28–30 Coronary angiography is generally considered to be the best available method of diagnosing CAD.

Coronary angiography is primarily restricted to identifying the degree of major epicardial vessel luminal stenosis. Furthermore, it cannot provide information regarding the patient’s exercise capacity, hemodynamic response to exercise, or functional status. Although coronary angiography is generally considered a relatively safe procedure, serious complications (including death, myocardial infarction, and embolization) have been reported. The rate of serious complication or death associated with coronary angiography is approximately 0.1 percent.29 Finally, of all the frequently used tests for diagnosing CAD, coronary angiography is the most expensive.

##### Noninvasive Testing

Noninvasive tests are often used in the workup of undifferentiated chest pain in outpatient or acute-care settings to provide incremental data and refine the pretest clinical suspicion of CAD. Patients with negative (i.e., normal) findings on noninvasive tests may be triaged to prevention and clinical observation management strategies, whereas patients with positive findings may be referred for coronary angiography in order to confirm the presence or absence of CAD. Supported by the literature, this approach has been used to refine the selection of patients with the highest likelihood of significant CAD and for whom revascularization may improve clinical outcomes, while at the same time minimizing unnecessary referrals for more expensive and potentially risky invasive testing. Patients with indeterminate or conflicting results on initial noninvasive testing may be triaged to either strategy (prevention and clinical observation or CA) or referred for additional testing. This determination is largely dependent on the posttest risk assessment by the clinician.

ECG. The standard clinical ECG detects the electrical field generated by the ion currents in cardiac cells through detection of potential differences on the skin surface. The signal is amplified, filtered, and displayed as a recording, which is then interpreted either computationally or by medical personnel.

Strengths and limitations of ECG. ECG is inexpensive, universally available, and broadly understood across medical disciplines. However, ECG lacks sufficiently high sensitivity for detection of CAD to be considered an adequate reference standard.7,8,31

Cardiac computed tomography (CCT). CCT uses modified software and hardware to acquire images of the luminal patency of the epicardial coronary arteries after administration of an intravenous contrast agent. Once obtained, the images are reformatted and reviewed for quantitative estimation of luminal narrowing in the coronary artery. If present, luminal narrowing is suggestive of CAD.32,33 Sensitivity is estimated to be 97 to 99 percent and specificity 88 to 93 percent for the diagnosis of CAD by 64-detector CCT.34

Strengths and limitations of CCT. CCT provides noninvasive anatomical detail of both the heart and the coronary arteries. CCT can identify unrelated or unsuspected diseases, which may or may not be related to the patient’s symptoms (e.g., lung mass, pulmonary embolus, or aortic dissection). Operating characteristics (sensitivity/specificity) compare well with currently used stress imaging studies. However, CCT is relatively expensive. The procedure involves radiation exposure and the administration of an intravenous contrast (thus, CCT is not appropriate for patients with renal insufficiency). The procedure does not readily identify CAD in distal segments of the coronary arteries. CCT is a relatively new technology; as such, there is limited information about how it correlates with long-term clinical outcomes.

Biomarkers. Patients with acute MI demonstrate elevations of serum cardiac biomedical markers (biomarkers) such as troponin or creatinine kinase (CK-MB). These values are usually elevated within 6 to 8 hours after onset of MI. Elevation of biomarkers carries prognostic value after MI; serial testing for such elevation is, therefore, part of the standard procedure used to diagnose MI.

Strengths and limitations of biomarkers. Tests of biomarkers are widely available, and results are rapidly and safely obtainable. Interpretation of findings is relatively straightforward. When measured serially, the troponin and CK-MB biomarkers carry high sensitivity (89 to 95%) and specificity (95%).35,36 Cardiac troponin is favored, since this marker provides greater specificity than CK-MB. However, since troponin results may remain elevated for up to 10 days, CK-MB is useful in assessing the timing of acute myocardial infarction.

However, biomarkers may be elevated in conditions unrelated to MI, so results must be interpreted in the context of clinical presentation and other available test results. Conditions unrelated to MI that may contribute to elevated biomarkers include sepsis, pulmonary embolus, renal failure, tachycardia, and valvular heart disease. Biomarkers have no role in screening for, or diagnosing, CAD outside of the presence of acute MI.

Stress testing with ECG. Exercise, when used as the stressor, can provide both diagnostic and prognostic information in patients with either suspected or known CAD. Both treadmill and bicycle protocols have been used to evaluate exercise time, intensity, and reproducibility of clinical symptoms. The standard 12-lead ECG, along with clinical symptoms and vital signs, is evaluated for changes during exercise. ECG criteria that have been standardized to suggest an abnormal test result rely on the finding of ST segment depression of 0.01mV (1 mm) that is horizontal or down sloping on three consecutive beats. Patients unable to exercise would normally undergo a pharmacologic stress test in conjunction with an imaging modality (see following section).

Strengths and limitations of stress testing with ECG. Stress testing is generally safe, widely available, well validated, and less costly compared with other forms of cardiac diagnostic tests. Stress testing can provide useful prognostic data. In a recent meta-analysis of the relevant studies, sensitivity and specificity were 68 percent and 77 percent, respectively, but values were lower among low-risk patients.28 A normal exercise ECG has excellent negative predictive value.

However, stress testing is associated with relatively high rates of false-positive results in women, and it cannot be reliably interpreted in patients with a variety of different baseline ECG abnormalities. Other limitations include difficult-to-interpret results in the setting of valvular heart disease, left ventricular hypertrophy, left bundle branch block, or patients on certain heart rate-lowering medications such as digoxin. Because of its low sensitivity, with correspondingly high likelihood of misclassifying patients, stress testing with ECG alone is not an adequate reference standard for CAD diagnosis.

Stress testing with imaging. The addition of a cardiac imaging component to the standard exercise ECG stress test is intended to improve test specificity by differentiating true-positive from false-positive ST segment depression during exercise. This differentiation is achieved through the absence of perfusion abnormalities (as in the case of myocardial perfusion imaging using single photon emission computed tomography) or left ventricular dysfunction (as in the case of stress echocardiography). Patients are typically imaged at baseline and then undergo ECG-monitored exercise, followed by imaging at peak exercise and recovery. Images are obtained for the purposes of detecting myocardial perfusion abnormalities or regional wall motion abnormalities. For single photon emission computed tomography, sensitivity is estimated to be 90 percent and specificity 72 percent.37 Exercise echocardiography is estimated to be 81 percent sensitive and 89 percent specific using stress-induced wall motion abnormalities.37

Strengths and limitations of stress testing with imaging. Stress testing with imaging is a well-validated diagnostic test for CAD, with a highly negative predictive value. The procedure is widely available and noninvasive. Results of stress testing with imaging can guide management and treatment recommendations. The procedure is considered an appropriate diagnostic test in patients with known or suspect CAD who are at low to intermediate risk for cardiovascular events.4 However, stress testing with imaging is relatively expensive as well as time-intensive. The procedure requires expertise in performance and interpretation. Also, it involves radiation exposure among patients injected with radiopharmaceuticals. Image quality for study interpretation may be limited in patients with suboptimal images due to attenuation artifacts from overlying soft tissue in single photon emission computed tomography or poor echocardiographic acoustic windows in patients who are obese or who have lung disease.

#### Tests for Diagnosing ACS

ACS is a term that is commonly used to describe the clinical presentation that includes acute onset of chest pain or other symptoms that suggest myocardial ischemia or infarct. ACS typically serves as a working diagnosis for such patients, pending the establishment or ruling out of specific diagnoses.2 There is no gold standard test for ACS. The standard ECG serves as one of the most important tests in the initial evaluation of patients who present with symptoms suggestive of ACS, but additional clinical and laboratory information is required to accurately differentiate patients with and without acute ischemic heart disease. Elevations in serum biomarkers such as creatine kinase (CK) MB fraction or troponin-I may indicate ischemia or infarct of the myocardium and may be used as an imperfect reference standard for the diagnosis of ACS.

## Summary for KQ 1

The strengths and limitations of the current diagnostic tests for the evaluation of suspected CAD and/or ACS represent the absence of a “one-size-fits-all” approach for cardiovascular risk assessment. In accordance with clinical guideline recommendations, the selection of the appropriate test must take into account the available expertise for both test performance and accurate test interpretation, while at the same time maximizing patient safety.38 In the research setting, we ideally want the best available reference test. Pragmatic clinical considerations, including guideline recommendations, legitimately influence this choice.

According to the ACC/AHA consensus guideline, coronary angiography remains the best reference standard for diagnosing CAD.29 Through interrogation and identification of the coronary anatomy, angiography is currently the best available test to identify which patients may benefit from surgical or percutaneous intervention, medical management, or both. Among low-risk patients who are typically not referred for coronary angiography but who undergo clinical observation and/or noninvasive testing instead, several noninvasive diagnostic tests have served as an acceptable reference standard. In these patients, results have correlated with the incidence of cardiovascular events. In particular, stress tests (with or without imaging) provide clinicians with incremental risk prediction that informs management and treatment decisions. Stress tests also provide prognostically important data that have been associated with patient outcomes such as exercise capacity, hemodynamic response, and magnitude of ST segment abnormalities.

Table 2 summarizes our findings that, according to current guidelines,29–32,34,35 coronary angiography remains the preferred reference standard for the diagnosis of CAD, while exercise stress testing with imaging serves as an acceptable reference standard. Appropriate use of biomarkers is an acceptable reference standard for the diagnosis of ACS but not of CAD. The standard 12-lead ECG is not an acceptable reference standard due to its poor accuracy in diagnosing CAD. In contrast, there is no gold standard diagnostic test for ACS, which is an “umbrella” term that serves primarily as a working diagnosis, pending results from further testing. In this context, the standard ECG provides critically important data that informs both the diagnosis and management of patients with ACS. Finally, elevated biomarkers such as CK-MP or troponin-I may be considered an acceptable, but imperfect, reference standard.

Table 2 Potential reference standards for diagnosing CAD^a^ or ACS

Reference Standard | Level of Acceptability
CAD
Coronary angiography | Preferred
Stress testing with imaging | Acceptable
Imaging studies without exercise or pharmacological stress; - Resting 12-lead ECG; - Stress testing with ECG | Unacceptable
ACS
Biomarkers (applicable only for identifying myocardial injury) | Acceptable

a Based on current guidelines.29–32,34,35

Abbreviations: CAD=coronary artery disease; ECG=electrocardiogram

## Analysis for KQ 2

Of the eight potentially relevant devices identified by the gray and published literature searches, only the PRIME ECG and the LP 3000 system were evaluated in published studies that met our inclusion criteria. We did not identify any studies meeting our eligibility criteria that reported on the Predictor, Model 1200 EPX, MAC 5000, 3DMP, CardioSoft, or HyperQ. We identified several published articles that evaluated the test performance of the 3DMP or the Predictor, but these studies did not meet inclusion criteria because the study population comprised patients with a high risk for CAD. We excluded two publications that evaluated the Procardio 5.0 because this device is neither FDA approved nor commercially available. The following sections are therefore restricted to analysis of PRIME ECG (10 studies) and LP 3000 (1 study).

### KQ 2a Evidence for Variability by Rater, Patient, or Device

Our search strategy did not identify any eligible studies that reported information on intra-rater, intra-patient, or intra-device variability. We identified a single fair-quality study that evaluated the inter-rater variability of the PRIME ECG device.39 This study involved 150 eligible patients who presented to an emergency department at times when both an emergency physician trained in BSM test interpretation and a clinical study assistant trained in the operation of the PRIME ECG were on duty. Study patients were administered both a standard ECG and a PRIME ECG test. Twenty-eight faculty or resident emergency physicians participated in this study; each had previously completed a 4-hour training session during which basic electropathophysiology, BSM device application, beat marker placement, and BSM interpretation were reviewed. All study physicians successfully passed an exam upon completion of the training session. The study also engaged three experts in BSM test interpretation. Standard ECG and PRIME ECG were provided electronically to these experts, none of whom had knowledge of patients’ clinical or laboratory data. Each BSM test was read by two expert raters. Discordant interpretations among the experts were adjudicated by a third.

Emergency physicians and BSM experts were charged with assigning each BSM reading into one of five categories: (1) normal, (2) nonspecific, (3) abnormal, (4) ischemia, or (5) infarction. The first two categories were considered to be a negative test result, and the latter three categories represented a positive test result. Of the 135 BSM tests interpreted by an expert reviewer, there was agreement between the emergency physicians and BSM experts on 52 (39%) for negative test result readings and 63 (47%) positive test result readings. Fifteen (11%) BSM tests were interpreted as negative by emergency physicians but positive by BSM experts, and 5 (4%) BSM tests were interpreted as positive by emergency physicians but negative by BSM experts. This result corresponds to a kappa statistic of 0.63 (95% CI, 0.53 to 0.72).

### KQ 2b Evidence for Test Performance

We identified 11 studies (represented by 14 articles) that evaluated the performance characteristics of a commercially available BSM or signal averaging ECG device (Table 3). All studies were prospective cohort studies, nine of which recruited consecutive patients. Ten studies (13 articles) evaluated the PRIME ECG BSM device.39–51 and one study evaluated the LP 3000 signal averaging ECG system.18 Ten of the eleven studies were considered fair quality because of (1) lack of details about the patient populations, (2) insufficient reporting of the methods and results, or (3) potential bias from lack of blinding by key study personnel.18,39–49 One study, the Optimal Cardiovascular Diagnostic Evaluation Enabling Faster Treatment of Myocardial Infarction (OCCULT MI) trial, was considered good quality.50,51 Of note, funding or material support for the PRIME ECG studies appeared to be linked to the manufacturer for all included studies of this device. This does not appear to be the case for the study of the LP 3000 system. We did not identify eligible studies that evaluated test performance or outcomes associated with the other eligible ECG-based signal averaging devices listed in Table 1 among patients that represented the target population for the purpose of this report. While screening articles for eligibility to meet inclusion criteria for this review, we separately looked for studies that addressed a population of asymptomatic patients. As noted previously, addressing use of these technologies in asymptomatic patients was not the purpose of this review. Surveying the availability of data for asymptomatic patients was a secondary interest of the research team and did not affect the inclusion/exclusion criteria used to identify evidence for the populations considered in this report. However, we think it worth noting that in the course of this additional task, we did not find any published studies that evaluated an ECG-based signal averaging device for the diagnosis of CAD and/or ACS in asymptomatic individuals.

Table 3 summarizes performance characteristics of the 11 studies included in this review.

Table 3 Performance characteristics of PRIME ECG and LP 3000 devices

Study ID | Included in Meta- analysis? | Study Quality | N Subjects | Setting | Threshold | Reference | Outcomes
PRIME ECG
Menown et al., 1998^40^ | Yes | Fair | Chest pain (n=314) | Emergency department, medical wards or mobile CCU; controls from WHO screening program | Not specified; developed from 28 variables via logistic regression | Acute MI; criteria not specified | Sensitivity=77% (123/160) Specificity=85% (131/154)
Menown et al., 2001^41^ | Yes | Fair | Ischemic-type chest pain<24 hours and 1 mm ST segment depression (n=24) | Cardiology via emergency department or mobile CCU | Algorithm: visual display using QRS Y ST-T isointegrals and ST60 isopotential + multivariate model | MI by chest pain >20 minutes + abnormal biomarkers | Sensitivity=88% (7/8) Specificity=75% (12/16) ECG Sensitivity=50% (4/8) Specificity=88% (14/16)
Mcclelland et al., 2003^42^ | Yes | Fair | Ischemic-type chest pain (n=103) | Cardiology via emergency department or mobile CCU | Algorithm: QRS width and axis, QRS and ST-T isointegrals, ST0 and ST60 isopotentials | MI by chest pain >20 minutes + abnormal biomarkers | Sensitivity=64% (34/53) Specificity=94% (47/50) ECG Sensitivity=45% (24/53) Specificity=94% (47/50)
Maynard et al., 2003^47^ | No | Fair | Ischemic-type chest pain (n=56) in the presence of left bundle branch block. Includes patients at high risk who were administered fibrinolytic therapy. | Acute medical cardiology unit in a tertiary hospital | Reversal of image | MI by abnormal biomarkers | Sensitivity=67% (12/18) Specificity=71% (27/38)
Carley et al., 2005^46^ | Yes | Fair | Ischemic-type chest pain, only low/moderate risk patients (n=211) | Emergency department at a university-affiliated teaching hospital | NR | MI by standard ECG criteria, abnormal biomarkers, or autopsy | Sensitivity=18% (3/17) Specificity=87% (169/194) ECG Sensitivity=0% (0/17) Specificity=96% (186/194)
Owens et al., 2006^49^ and Navarro et al., 2003^43^ | Yes | Fair | Ischemic-type chest pain (n=427). Combined training and validation sets. | Cardiology via emergency department or mobile CCU | Algorithm: epicardial – ST0 isopotential from subset of study sample | MI by abnormal biomarkers | Physician-read BSM Sensitivity=75% (154/205) Specificity=91% (202/222) ECG Sensitivity=60% (123/205) Specificity=99% (220/222)
Owens et al., 2008^45^ and Owens et al., 2004^44^ | Yes | Fair | Ischemic-type chest pain (n=755) | Cardiology via emergency department or mobile CCU | Region specific ST segment elevation on isopotential map | MI by abnormal biomarkers | Sensitivity=76% (402/529) Specificity=92% (208/226) ECG Sensitivity=45% (238/529) Specificity=92% (208/226)
Fermann et al., 2009^39^ | Yes | Fair | Ischemic-type chest pain (n =150) | Emergency department at an urban tertiary care hospital | NR. Data reported for both any abnormality on index test and abnormalities not known to be old. We report results of any abnormality on ECG or PRIME ECG test | Three separate criteria:; 1. MI by abnormal biomarkers or >70% stenosis or abnormal noninvasive testing or CABG; 2. MI by abnormal biomarkers or >70% stenosis or abnormal noninvasive testing or CABG or discharge diagnosis of MI or ACS; 3. MI by abnormal biomarkers or >70% stenosis or abnormal noninvasive testing or CABG or discharge diagnosis of MI or ACS or postdischarge event | [underlined: Criteria 1:] Sensitivity=63% Specificity=60% ECG Sensitivity=53% Specificity=63% [underlined: Criteria 2:] Sensitivity=64% Specificity=59% ECG Sensitivity=59% Specificity=65% [underlined: Criteria 3:] Sensitivity=40% Specificity=60% ECG Sensitivity=60% Specificity=66%
O’Neil et al., 2010^50^ and Hoekstra et al., 2009^51^ | Yes | Good | Chest pain or symptoms suspicious for ACS [underlined: without] STEMI (n=1513) | High-volume tertiary care center emergency departments in United States | Core laboratory with cardiologists and emergency physicians blinded to clinical results and test readings | MI: final diagnosis of NSTEMI or UA, with any elevated troponin ACS: according to the ACC/AHA guideline for the diagnosis of ACS | [underlined: MI] Sensitivity=19% (40/206) Specificity=94% (1227/1307) ECG Sensitivity=11% (22/206) Specificity=96% (1260/1307) [underlined: ACS] Sensitivity=12% (50/408) Specificity=94% (1035/1105) ECG Sensitivity=7% (29/408) Specificity=96% (1065/1105)
Ornato et al., 2009^48^ | Yes | Fair | Patients suspected of having ACS (n=589) | Emergency departments | ST J-point elevation of prespecified magnitude and location | 2 separate criteria:; 1. elevated CK-MB; 2. elevated troponin | [underlined: Criteria 1 (n=364):] Sensitivity=100% (22/22) Specificity=96% (330/342) ECG Sensitivity=73% (16/22) Specificity=97% (332/342) [underlined: Criteria 2 (n=225):] Sensitivity=93% (26/28) Specificity=95% (187/197) ECG Sensitivity=61% (17/28) Specificity=96% (189/197)
LP 3000
Michaelides et al., 1999^18^ | No | Fair | Typical angina (n=126) | Hospital in Greece | QRS prolongation >5 msec | CAD by coronary angiography | Sensitivity=69% (75/108) Specificity=89% (16/18) ECG Sensitivity=56% (60/108) Specificity=89% (16/18)

Abbreviations: ACC=American College of Cardiology; AHA=American Heart Association; BSM=body surface mapping; CAD=coronary artery disease; CCU=cardiac care unit; ECG=electrocardiogram; MI=myocardial infarction; msec=millisecond; WHO=World Health Organization

#### PRIME ECG Device

Of the 10 eligible studies evaluating the test performance of the PRIME ECG BSM device, 6 were conducted by a research group in Belfast, Ireland. These investigators published 8 eligible articles from 1998 to 2008 on sequential series of consecutive patients with ischemic-like chest pain as they presented to a 24-hour physician-manned mobile coronary care unit (cardiac ambulance), the emergency department, or medical wards in Northern Ireland.40–45,47,49 Excluding one study47 of a subsample of 56 patients recruited from 1995 to 1999 with left bundle branch block, which may have included data reported in another eligible publication, and excluding data obtained from patients that contributed to training sets in preparation for validation datasets, this series of articles appears to represent a total of 2274 patients recruited from 1995 to 2004. It was unclear whether these mobile coronary care units in Ireland served a population with chest pain similar to the population served by U.S. emergency departments, or if the units tended to serve patients triaged to be at high risk for acute myocardial ischemia. A study sample with more severe CAD would be expected to bias test performance toward greater sensitivity.

Because the PRIME ECG device algorithm is evolving, the interpretation methods and potentially the accuracy of the device may have changed over time. In the initial study published in 1998,^40^ a regression model was developed from 28 candidate variables. In later studies, slightly different criteria (sometimes specified a priori and in other instances apparently derived from the data) were described. In one study of the PRIME ECG, the authors stated, “We acknowledge that the performance of the algorithm used in this study is disappointing, particularly in terms of specificity, and we are currently developing an algorithm to improve specificity whilst maintaining sensitivity.”43

The changing criteria for an abnormal PRIME ECG result could lead to variable performance across our included studies. Furthermore, criteria derived from the observed data could overestimate accuracy. In all studies, the PRIME ECG was compared to cardiac biomarkers, which served as a test for myocardial injury. Some studies either used a single set of biomarkers or did not specify the number of sets obtained. Three studies specified that the PRIME ECG was blindly interpreted and compared to the reference standard. Only one study described the reference standard as blindly interpreted relative to the PRIME ECG. If abnormal ranges for cardiac biomarkers were prespecified, it is unlikely that interpretation would be influenced by the index test results.

One study from this research group included in this report involved 56 patients who presented with chest pain suggestive of acute MI in the presence of left bundle branch block on the initial ECG.47 These patients were among the consecutive patients admitted to the acute medical cardiology unit included in the early published articles by the research group in Belfast, Ireland. This subset of patients was recruited between September, 1995, and November, 1999. At that time, the standard of care included initiating thrombolytic therapy in patients with left bundle branch block when acute MI was suspected. The PRIME ECG was administered before or within 15 minutes of administering thrombolytic therapy among the patients in this series who were treated with thrombolytics. In this sample of 56 patients, the sensitivity and specificity of the PRIME ECG in identifying acute MI as diagnosed by elevated biomarkers was 67 percent and 71 percent, respectively. A positive PRIME ECG test result—defined as loss of mirror image reversal in the comparison of QRS and ST-T isointegral maps—was associated with a significantly higher risk of having an acute MI (odds ratio [OR] 4.9; 95% CI, 1.5 to 16.4; p=0.007). We excluded this study and its data from our meta-analysis because of the likelihood of duplicate data and because the other studies used different criteria for defining a positive result in patients with left bundle branch block, in which ST elevation on the ECG was not a valid indicator of acute MI.

The research group from Ireland contributed data to another study included in this report,48 along with data from consecutive patients recruited from emergency departments in two hospitals in the United States and one in England. A total of 647 adults from these 4 recruitment sites who presented to the emergency department within 12 hours of onset of symptoms consistent with or suggestive of acute MI or unstable angina met inclusion criteria and consented to participate. Of these, 589 patients with standard ECG, PRIME ECG, and biomarker data were included in the analysis. Test performance was calculated for both the standard ECG and the PRIME ECG compared with elevated CK-MB enzymes (n=364) and to elevated troponin levels (n=225) for diagnosing acute MI. With CK-MB enzyme elevation as the gold standard, the sensitivity and specificity for the PRIME ECG was 100 percent and 97 percent, respectively, compared with 73 percent and 97 percent for the standard ECG. With troponin elevation as the gold standard, the sensitivity and specificity were 93 percent and 95 percent, respectively, for the PRIME ECG and 61 percent and 96 percent for the standard ECG.

We identified two eligible articles from the multicenter, prospective, cohort-blinded OCCULT MI trial.50,51 This study evaluated the PRIME ECG among 1830 adults at high to moderate risk for adverse cardiovascular outcomes who presented to a tertiary care emergency department in the United States with chest pain or symptoms suspicious for ACS. Results were reported separately for patients who ultimately received a study-adjudicated diagnosis of STEMI (n=91), NSTEMI or unstable angina (n=206), or non-MI ACS (n=408). Most of the patients who ultimately received a study-adjudicated diagnosis of STEMI had ST elevations on ECG at presentation and as such were known to be high risk for CAD prior to administration of the PRIME ECG. Therefore, since our report focuses on patients at low to intermediate risk for CAD with symptoms suggestive of ACS, we report only the data from patients in this study who ultimately received a study-adjudicated diagnosis of NSTEMI, unstable angina, or ACS. Among the NSTEMI or unstable angina patients, sensitivity and specificity were 19.4 percent (95% CI, 14.6 to 25.4) and 93.9 percent (CI, 92.4 to 95.1), respectively, for the PRIME ECG and 10.7 percent (CI, 7.1 to 15.7) and 96.4 percent (CI, 95.2 to 97.3), respectively, for the 12-lead ECG. Among the ACS patients, sensitivity and specificity were 12.3 percent (CI, 9.4 to 15.8) and 93.7 percent (CI: 92.1 to 95.0), respectively, for the PRIME ECG and 7.1 percent (CI, 5.0 to 10.0) and 96.4 percent (CI, 95.1 to 97.3), respectively, for the 12-lead ECG. This is the only study included in our report that evaluated the test performance of the PRIME ECG for both NSTEMI and ACS patients; for consistency, we used the sensitivity and specificity data among the NSTEMI sample in our meta-analysis reported below.

A study that involved 150 patients with ischemic-type chest pain recruited from an emergency department at an urban tertiary care hospital was conducted in the United States.39 Three separate sets of criteria were used to define MI or ACS: (1) abnormal biomarkers or greater than 70 percent coronary artery stenosis by cardiac catheter evaluation or abnormal noninvasive testing or revascularization, (2) in addition to first criteria, a diagnosis of MI or ACS at time of discharge from the hospital, and (3) in addition to the first and second criteria, a postdischarge event, defined as a repeated visit to the emergency department with chest pain or ischemic symptoms, recurrent MI, catheterization, revascularization, or death. Sensitivity and specificity for the PRIME ECG were 63 percent and 59 percent for the first criteria, 64 percent and 59 percent for the second criteria, and 40 percent and 60 percent for the third criteria. In comparison, sensitivity and specificity for the 12-lead ECG were 53 percent and 63 percent for the first criteria, 59 percent and 65 percent for the second criteria, and 60 percent and 66 percent for the third criteria. The first criteria is most similar to the gold standard for diagnosis of acute MI used in the other studies in this report; for this reason, we included the sensitivity and specificity estimates with the first criteria as the gold standard in our meta-analysis, reported below.

The last of the eligible studies on the PRIME ECG device included in this report involved 211 patients with ischemic-type chest pain who were specifically identified at time of enrollment to be of low or moderate risk for CAD.46 Patients were recruited from the emergency department at a university-affiliated teaching hospital in Manchester, England. MI was defined by standard ECG criteria, abnormal cardiac biomarkers, or autopsy. In this population, the sensitivity of the PRIME ECG was 18 percent and the specificity 87 percent, respectively, compared with zero percent and 95 percent for the standard ECG.

#### LP 3000 Signal Averaging System

The one eligible study we identified that evaluated a signal averaging ECG device was conducted in Greece and published in 1999.^18^ This study was a prospective cohort study with coronary angiography as the criterion for diagnosing clinically significant CAD. In this study, 126 consecutive patients referred to a hospital for a first period of typical angina underwent both standard ECG and testing with the LP 3000 signal averaging ECG system. All patients also underwent coronary angiography. The signal averaging ECG test was considered positive in the presence of QRS prolongation of more than 5 milliseconds. QRS prolongation on the signal averaging ECG was associated with a sensitivity and specificity of 70 percent and 89 percent, respectively, compared to 56 percent and 89 percent for ST changes detected by 12-lead ECG. The improved sensitivity of signal averaging ECG relative to 12-lead ECG was statistically significant (p<0.01).

#### Meta-Analysis for KQ 2b

Device performance was summarized using sensitivity, specificity, and likelihood ratios. Test sensitivity describes the proportion of subjects with disease who have an abnormal test. Test specificity describes the proportion of subjects without disease who have a normal test. A likelihood ratio (LR) is a measure that may be more useful to clinicians since a simple nomogram allows posttest disease probabilities to be readily calculated. The positive likelihood ratio (LR+) describes how many times more likely it is that an abnormal test comes from a patient with disease versus a patient without disease. The negative likelihood ratio (LR–) describes how many times more likely it is that a normal test comes from a patient with disease versus a patient without disease. The posttest probabilities for negative and positive results were calculated on the basis of assumed prevalence and LR+ and LR- obtained from the meta-analysis. A LR+ greater than 10 and LR- less 0.1 imply strong effects, whereas an LR close to 1 implies no effect. Positive and negative LRs with corresponding CIs for each diagnostic method were calculated from the mean logit-sensitivity and mean logit-specificity and their corresponding standard errors.

When studies were conceptually homogeneous, we used a bivariate random-effects generalized linear regression model to compute summary estimates of sensitivity and specificity with 95 percent confidence intervals.14,52,53 A random-effects model assumes that variability is a result of sampling errors as well as the true differences between studies. Also, it provides a meta-analytic modeling approach for pooling sensitivity and specificity while accounting for possible correlation between sensitivities and specificities of the studies included.15 For studies that derived a test algorithm in a training set and tested performance in a validation set, we analyzed performance characteristics from the validation set.

We evaluated statistical heterogeneity by inspecting forest plots and computing Q and I^2^ statistics. Since the Q test is underpowered, we set the threshold for significant heterogeneity at p<0.10. For the I^2^ test, a suggested interpretation is to assign the terms low, moderate, and high to I^2^ values of 25 percent, 50 percent, and 75 percent, respectively.16 The mean sensitivity and mean specificity of each diagnostic method were compared using a paired Z-test. A P-value ≤0.05 was considered statistically significant. Analyses were performed with software (SAS, version 9.1, SAS Institute, Cary, NC; Excel, version 5.0, Microsoft, Bedford, WA; and Comprehensive Meta-Analysis version 2.0, Englewood, NJ).

We used a bivariate random-effects model to combine results across the 10 included PRIME ECG studies (Table 4). The sensitivity and specificity were 71.1 percent (95% CI, 45.6 to 87.8) and 90.2 percent (CI, 83.2 to 94.4), respectively. Studies were statistically heterogeneous for the LR+ (Q=122.9, df=9, p<0.001; I^2^=92.7%) and for the LR- (Q=314.9, df=9, p<0.001; I^2^=97.1%). The summary estimate for the LR+ was 6.3 (CI, 3.3 to 12.1) and for the LR- was 0.30 (CI, 0.16 to 0.56). Using these estimates of test performance, an abnormal PRIME ECG test in a patient with a pretest probability for clinically significant CAD of 50 percent would yield a posttest probability of 86.3 percent. A normal PRIME ECG would yield a posttest probability of 23.1 percent (Figure 4). To summarize PRIME ECG diagnostic performance, each pair of true positive rates (sensitivity) and false positive rates (1-specificity) is shown with a summary receiver operating characteristic (SROC) curve as a way to display variations in threshold for test positivity (Figure 5).54

We performed a sensitivity analysis excluding two studies, namely, the initial study that most clearly used a different diagnostic algorithm40 and a second study with a very small sample size that was disproportionately weighted in the random-effects meta-analysis.41 The standard errors of the effect measures are determined by two factors—the number of subjects and the measure of interest in the compared groups. These factors in turn determine the weight given to a study in the meta-analysis. If one or both of these factors differ (are outliers) from the other studies included, the results can be overestimated or underestimated.55 The sensitivity and specificity for the remaining studies were 68.4 percent (CI, 35.1 to 89.7) and 91.4 percent (CI, 83.6 to 95.7), respectively. The remaining studies were heterogeneous for the LR+ (Q=122.1, df=7, p<0.001, I^2^=94.3%) and LR- (Q=277.4, df=7, p<0.001, I^2^=97.5%). The LR+ (6.7; CI, 2.8 to 15.9) and LR-(0.31; CI, 0.14 to 0.69) were not substantially changed. Using these estimates of test performance, an abnormal PRIME ECG test in a patient with a pretest probability for clinically significant CAD of 50 percent would yield a posttest probability of 87.0 percent. A normal PRIME ECG would yield a posttest probability of 23.7 percent.

For the 10 studies that evaluated the 12-lead ECG, we computed performance characteristics in the same manner (Table 5). The sensitivity and specificity were 43.1 percent (95% CI, 25.8 to 62.2) and 94.4 percent (CI, 88.4 to 97.4), respectively. There was significant heterogeneity for both the LR+ (Q=89.8, df=9, p<0.001; I^2^=90.0%) and LR- (Q=209.5, df=9, p<0.001; I^2^=95.7%). The 12-lead ECG had a summary LR+ of 7.2 (CI 3.2 to 16.3) and LR- of 0.57 (0.44 to 0.74). Using these estimates of test performance, in a patient with a pretest probability for clinically significant CAD of 50 percent, a standard 12-lead ECG suggesting ischemia would yield a posttest probability of 87.8 percent. A standard 12-lead ECG without evidence of ischemia would yield a posttest probability of 36.3 percent (Figure 4). To assess standard 12-lead ECG diagnostic performance, each pair of true positive rates (sensitivity) and false positive rates (1-specificity) is shown with an SROC curve (Figure 5).

We performed a sensitivity analysis excluding the study with a very small sample size and the study not evaluating PRIME ECG performance.18, 41 The sensitivity and specificity for the remaining studies were 40.5 percent (95% CI, 19.6 to 65.5) and 95.0 percent (CI, 87.9 to 98.0), respectively. The remaining studies were heterogeneous for the LR+ (Q=89.7, df=7, p<0.001, I^2^=92.2%) and LR- (Q=195.4, df=7, p<0.001, I^2^=96.4%). The LR+ (7.0; CI 3.0 to 6.7) and LR- (0.61; 0.48 to 0.78) were not substantially changed. Using these latter estimates of test performance, in a patient with a pretest probability for clinically significant CAD of 50 percent, a standard 12-lead ECG suggesting ischemia would yield a posttest probability of 88.2 percent. A standard 12-lead ECG without evidence of ischemia would yield a posttest probability of 36.7 percent.

The 12-lead ECG had a slightly higher LR+ (a positive test increases the likelihood of disease), but the PRIME ECG had a lower LR− (a negative test lowers the likelihood of disease). However, using a paired Z-test, neither the LR+ nor the LR− was statistically significant when comparing diagnostic methods, p<0.21 and p<0.08, respectively.56

A bivariate meta-regression by time analysis was used to determine if the sensitivities and specificities changed over time. For the PRIME ECG, both sensitivity and specificity decreased slightly but not significantly as time increased (p<0.81). However, for the standard ECG, both sensitivity and specificity slightly increased but not significantly as time increased (p<0.47).

All studies used myocardial injury as the reference standard and included subjects with ischemic-type chest pain. Patients with ischemic-type chest pain certainly form an important subgroup of the target population, but patients at lower risk for CAD (such as individuals with atypical chest pain) were not included. Applicability was also limited by the reference standard. Myocardial injury is an important outcome of interest, but clinicians are also concerned with identifying patients with acute ischemic heart disease prior to myocardial injury.

Figure 4 Posttest probabilities as a function of prevalence for PRIME ECG and standard 12-lead ECG

Figure 4 displays the posttest probabilities for the negative likelihood ratio and positive likelihood ratio as a function of pretest prevalence for each diagnostic method. The posttest probabilities for negative and positive results were calculated on the basis of prevalence, and the positive and negative likelihood ratios were obtained from the bivariate meta-analysis. Using the estimates of test performance, an abnormal PRIME ECG test in a patient with a pretest probability for clinically significant CAD of 50 percent would yield a posttest probability of 86.3 percent. A normal PRIME ECG would yield a posttest probability of 23.1 percent. In a patient with a pretest probability for clinically significant CAD of 50 percent, a standard 12-lead ECG suggesting ischemia would yield a posttest probability of 87.8 percent. A standard 12-lead ECG without evidence of ischemia would yield a posttest probability of 36.3 percent.

Figure 5 Summary receiver operating characteristic curves for Prime ECG and standard 12-lead ECG

Figure 5 displays the summary receiver operating characteristic curves as well as the true positive rate (sensitivity) and false positive rate (1-specificity) pairs for each study and diagnostic method.

Table 4 PRIME ECG performance characteristics

Study ID | Sample Size | Sensitivity | Specificity | Positive Likelihood Ratio | Negative Likelihood Ratio
Menown et al., 1998^40^ | 314 | 76.9% | 85.1% | 5.1 | 0.27
Menown et al., 2001^41^ | 24 | 87.5% | 75.0% | 3.5 | 0.17
Mcclelland et al., 2003^42^ | 103 | 64.2% | 94.0% | 10.7 | 0.38
Maynard et al., 2003^47^ | 56 | 66.7% | 71.1% | 2.3 | 0.47
Carley et al., 2005^46^ | 211 | 17.6% | 87.1% | 1.4 | 0.94
Owens et al., 2006^49^ and Navarro et al., 2003^43^ | 427 | 75.1% | 91.0% | 8.3 | 0.27
Owens et al., 2008^45^ and Owens et al., 2004^44^ | 755 | 76.0% | 92.0% | 9.5 | 0.26
Ornato et al., 2009^48^ [underlined: CK-MB] [underlined: Troponin] | 364 25 | 100.0% 92.9% | 96.5% 94.9% | 26.8 18.3 | 0.02 0.08
Fermann et al., 2009^39^ | 150 | 63.4% | 59.6% | 1.6 | 0.61
O’Neil et al., 2010^50^ and Hoekstra et al., 2009^51^ | 1513 | 19.4% | 93.9% | 3.2 | 0.86
Summary (95% CI) * Omits Maynard et al., 2003^47^ | 4086 | 71.1% (45.6% to 87.8%) | 90.2% (83.2% to 94.4%) | 6.3 (3.3 to 12.1) | 0.30 (0.16 to 0.56)
Summary (95% CI) ** Omits Maynard et al., 2003,^47^ Menown et al., 1998,^40^ and Menown et al., 2001^41^ | 3748 | 68.4% (35.1% to 89.7%) | 91.4% (83.6% to 95.7%) | 6.7 (2.8 to 15.9) | 0.31 (0.14 to 0.69)

* One of the 11 studies47 was omitted from the meta-analysis because it included patients with left bundle branch block.

** Three studies were omitted because of the presence of bundle branch block in patients,47 use of a different algorithm,40 and a very small sample size that was disproportionately weighted in the random-effects meta-analysis.41

Abbreviations: CI=confidence interval; CK-MB=creatine kinase-MB fraction; ECG=electrocardiogram

Table 5 12-lead ECG performance characteristics

Study ID | Sample Size | Sensitivity | Specificity | Positive Likelihood Ratio | Negative Likelihood Ratio
Menown et al., 2001^41^ | 24 | 50.0% | 87.5% | 4.0 | 0.57
Mcclelland et al., 2003^42^ | 103 | 45.3% | 94.0% | 7.5 | 0.58
Carley et al., 2005^46^ | 211 | 0.0% | 95.9% | 0.64 | 1.0
Owens et al., 2006^49^ and Navarro et al., 2003^43^ | 427 | 60.0% | 99.1% | 66.6 | 0.40
Owens et al., 2008^45^ and Owens et al., 2004^44^ | 755 | 45.0% | 92.0% | 5.6 | 0.60
Ornato et al., 2009^48^ [underlined: CK-MB] [underlined: Troponin] | 364 225 | 72.7% 60.7% | 97.1% 95.9% | 24.9 15.0 | 0.28 0.41
Fermann et al., 2009^39^ | 150 | 52.7% | 63.2% | 1.4 | 0.75
O’Neil et al., 2010^50^ and Hoekstra et al., 2009^51^ | 1513 | 10.7% | 96.4% | 3.0 | 0.93
Michaelides et al., 1999^18^ | 126 | 55.6% | 88.9% | 5.0 | 0.50
Summary (95% CI) | 3898 | 43.1% (25.8% to 62.2%) | 94.4% (88.4% to 97.4%) | 7.2 (3.2 to 16.3) | 0.57 (0.44 to 0.74)
Summary (95% CI) *Omits Menown et al., 2001^41^ | 3874 | 42.4% (23.6% to 63.8%) | 94.7% (88.3% to 97.7%) | 7.5 (3.1 to 18.4) | 0.57 (0.43 to 0.75)
Summary (95% CI) **Omits Menown et al., 2001^41^ and Michaelides et al., 1999^18^ | 3748 | 40.5% (19.6% to 65.5%) | 95.0% (87.9% to 98.0%) | 7.0 (3.0 to 6.7) | 0.61 (0.48 to 0.78)

* One of the 11 studies41 was omitted from the meta-analysis because it included patients with left bundle branch block.

** Two studies were omitted because of small sample size41 and no evaluation of PRIME ECG performance.18

Abbreviations: CI=confidence interval; CK-MB=creatine kinase-MB fraction; ECG=electrocardiogram

### KQ 2c Evidence for Impact on Diagnostic Decisionmaking

Our search did not identify any eligible studies that provided evidence that the use of, or findings from, ECG-based technologies other than the standard 12-lead ECG had an impact on the decisions or actions of patients or health care providers.

### KQ 2d Evidence for Impact on Patient Outcomes

We identified two studies represented by three articles that collected data on long-term patient outcomes. The multicenter, prospective, cohort-blinded OCCULT MI trial50,51 evaluated the PRIME ECG among 1830 adults at high to moderate risk for adverse cardiovascular outcomes who presented to a tertiary care emergency department with chest pain or symptoms suspicious for ACS. The primary aim of this good-quality study was to test the hypothesis that individuals with STEMI detected only by the PRIME ECG would have similar angiographic pathology and similar mortality and morbidity rates compared with individuals with STEMI detected by standard ECG. A preplanned secondary analysis compared outcomes of patients with STEMI with those without STEMI. Among the 1513 patients with available outcome data, ST elevation detected by the PRIME ECG was associated with increased mortality (OR 11.2; 95% CI, 1.8 to 67). ST elevation on a standard 12-lead ECG, however, was not predictive of adverse outcomes in this sample of patients. There are at least two interpretations of these findings: (1) the PRIME ECG device correctly identified patients that had a false-negative ECG, or (2) a positive test result on the PRIME ECG device may influence clinical decisionmaking in a way that results in harm, relative to the standard ECG. Implications of this finding on the need for further research are discussed in the Future Research section that follows.

We identified a fair-quality study that collected information about the impact of testing on patient outcomes but did not report those outcomes. That study collected information obtained from patients through the course of their hospital stay and after discharge (such as repeat visits to the emergency department with chest pain or ischemic symptoms, recurrent MI, catheterization, revascularization, or death). These patient outcomes, however, were not reported in the published paper.

## Summary for KQ 2

In summary, we found two ECG-based signal analysis devices for which there were English-language, peer-reviewed studies of patients at low to intermediate risk for CAD who present with acute-onset chest pain or other symptoms suggestive of ACS. These devices were the PRIME ECG and the LP 3000 signal averaging system. Only one study reported inter-rater variability data. This study demonstrated that attending and resident emergency physicians had reasonably good agreement with experts in BSM interpretation in identifying negative versus positive findings on the BSM device after undergoing a 4-hour training session. Nine studies used elevated biomarkers as the criterion standard for comparing the test performance of the PRIME ECG relative to the standard ECG. One study, the OCCULT MI trial, evaluated both test performance and prognostic utility of the PRIME ECG relative to the standard ECG, using a comprehensive criterion standard that resulted in study-adjudicated diagnoses of MI or ACS. Meta-analysis of the 8 studies that evaluated the PRIME ECG demonstrated 68.4 percent sensitivity (95% CI, 35.1 to 89.7) and 91.4 percent specificity (CI, 83.6 to 95.7) for detecting MI (with all but one study using elevated cardiac biomarkers as the reference standard). Meta-analysis of the same eight studies that evaluated the 12-lead ECG demonstrated 40.5 percent sensitivity (CI, 19.6 to 65.5) and 95.0 percent specificity (CI, 87.9 to 98.0) for detecting MI. The 12-lead ECG had a slightly higher LR+ (a positive test increases the likelihood of disease), but the PRIME ECG had a lower LR− (a negative test lowers the likelihood of disease). However, using a paired Z-test, neither the LR+ nor the LR- was statistically significant when comparing diagnostic methods, p<0.21 and p<0.08, respectively.

The study that compared the LP 3000 with the standard ECG to identify patients with clinically significant CAD used coronary angiography as the criterion standard. Results from this study suggest that the LP 3000 may have higher sensitivity and specificity than the standard ECG for identifying patients with ACS who have clinically significant CAD.

We did not identify any studies that directly assessed the impact of ECG-based signal analysis devices on clinical decisionmaking. We identified two studies that collected long-term outcome data, but one of them did not report those findings. The one study that reported long-term patient outcomes found that, among 1513patients who did not have STEMI, ST elevation detected by the PRIME ECG was associated with increased mortality (OR 11.2; 95% CI, 1.8 to 67). ST elevation on a standard 12-lead ECG, however, was not predictive of adverse outcomes in this sample of patients.