# Methods

## Key Questions

The sponsor of this report identified two key questions (KQs) to be addressed. The EPC research team further clarified these questions and research objectives through consultation with the AHRQ Task Order Officer assigned to the project and representatives from CMS.

At the most general level, the objectives of this report were to (1) identify and describe devices and methods for ECG-based signal analysis that are currently being used, or proposed to be used, for the diagnosis of CAD and/or ACS and (2) summarize the available clinical and scientific evidence on the use of ECG-based signal analysis technologies for the noninvasive diagnosis of suspected CAD and/or ACS in the ambulatory or emergency settings. These questions can be further broken down as follows:

### KQ 1

a. What devices and methods for ECG-based signal analysis are used, or proposed to be used, for diagnosis of CAD and/or acute coronary syndrome (with or without chest pain) in outpatient settings (including physician offices, urgent care, and emergency departments) in patients at low to intermediate risk? What is the U.S. Food and Drug Administration (FDA) status of these devices?
b. What are considered the “gold standard” tests for the diagnosis of CAD and/or acute coronary syndrome (with or without chest pain) in patients at low to intermediate risk, and what are their strengths and limitations?

### KQ 2

a. What is the evidence for inter-rater, intra-rater, intra-patient, and intra-device variability?
b. What is the evidence for diagnostic test performance compared to the reference standard used in the study? What factors (confounders) affect test sensitivity and specificity?
c. What is the evidence that ECG-based signal analysis technologies impact diagnostic decisionmaking?
d. What is the evidence that ECG-based signal analysis technologies impact patient outcomes?

## Analytic Framework

We developed an analytic framework based on principles from Fryback and Thornbury’s hierarchical model of diagnostic efficacy.9 This framework proposes a multilevel evaluation of diagnostic tests, beginning with studies of variability, progressing through diagnostic test performance, and ending with the effects on relevant patient outcomes. This analytic framework, shown in Figure 2, guided our research questions, search strategy, data abstraction elements, and evaluations.

Our analytic framework defines the target population as patients at low to intermediate risk for CAD who present with chest pain or other symptoms suggestive of ACS. Diagnostic tests depicted in the framework include the standard 12-lead ECG, other ECG-based technologies, a criterion standard such as coronary angiography, or other diagnostic tests. Potential outcomes evaluated include technical accuracy efficacy, diagnostic accuracy efficacy, diagnostic thinking efficacy, and patient outcome efficacy. Patient outcomes include catheterization laboratory findings, clinical outcomes of mortality, cardiac symptoms, function and functional status, and therapeutic interventions.

Figure 2 Analytic framework

Abbreviations: ACS=acute coronary syndrome; CAD=coronary artery disease; ECG=electrocardiogram; KQ=key question

Figure 2 shows the key questions within the context of the patient population of interest, the available diagnostic tests, and the outcomes considered in this report. Patients are those adults at low to intermediate risk of coronary artery disease who present with chest pain or other symptoms suggestive of acute coronary syndrome. Key Question 1a considers which devices and methods for ECG-based signal analysis are used, or are proposed to be used, for diagnosis of CAD and/or acute coronary syndrome (with or without chest pain) in outpatient settings (including physician offices, urgent care, and emergency departments) for patients at low to intermediate risk, as well as the FDA status of these devices. Key Question 1b considers which tests are the “gold standard” tests for the diagnosis of CAD and/or acute coronary syndrome as well as their strengths and limitations. Key Question 2a considers the technical accuracy efficacy of the tests, including inter-rater and intra-rater variability, intra-patient variability, and intra-device variability. Key Question 2b considers the diagnostic accuracy efficacy including sensitivity, specificity, positive predictive value, and negative predictive value. Key Question 2c considers the diagnostic thinking efficacy and therapeutic efficacy including the impact on diagnostic decisionmaking. Key Question 2d considers patient outcome efficacy.

## Approach

### Sources of Information and Review Methods

The sources of information as well as the review methods used by the EPC varied according to the KQ being addressed. Both KQs 1 and 2 required systematic literature search strategies, but the data collected from the two strategies were quite different. For KQ 1, we conducted a comprehensive review of the published and gray literature and gathered and collated information from the FDA, device manufacturers, and other relevant sources (see search strategies provided in Appendix A). KQ 1 also involved summarizing information about commonly used diagnostic tests, procedures, and strategies. For KQ 2, we searched published, peer-reviewed literature to synthesize the available scientific evidence pertaining to ECG-based signal analysis technologies that may potentially be applicable to the diagnosis of CAD in a patient without known CAD but who presents with chest pain or who has a clinical presentation suggestive of ACS.

### Process for Study Selection

We conducted a systematic search of the English-language literature indexed in PubMed^®^, Embase, and the Cochrane Database of Systematic Reviews and Database of Abstracts of Reviews of Effects, and a search of gray literature sources including the U.S. FDA Web site, Google™, online journal websites, professional society conference abstracts, www.clinicaltrials.gov, and www.freepatentsonline.com. We sought to identify devices that improved the diagnosis of CAD and/or ACS through the use of signal analysis, signal averaging, spectral analysis, or other forms of advanced data transformation. We specifically excluded devices that used imaging techniques such as echocardiography or coronary angiography as well as technologies that did not analyze electrocardiographic information. We initially included magnetocardiography in our published literature search strategy but later excluded this technology on the grounds that it involves more than the application of a single device and is not readily available at most medical facilities. We identified the major categories of electrocardiography, including body surface potential mapping, mathematical analysis of ECG signals, and vectorcardiography.

After discussions with representatives from CMS, we narrowed our focus to devices that (1) obtain and interpret information about the heart’s electrical activity, (2) interpret the electrical signal in a novel way using mathematical manipulation of data (e.g., fast Fourier transform or spatial imaging), and (3) interpret specifically for the purpose of diagnosing CAD or myocardial ischemia. We used the above-stated criteria to define ECG-based signal analysis devices for the purpose of this report.

We limited our search to named devices for which we could identify a manufacturer or distributor. We reviewed all of the studies identified that reported on any device or method that met our inclusion criteria. We excluded devices for which we could not find evidence of commercial availability.

### Literature Search Strategies

We devised two main strategies for gathering information. First, we conducted an extensive search of the gray literature on this subject. A single investigator searched each of the general gray literature sources listed in Appendix A including the ClinicalTrials.gov Web site (www.clinicaltrials.gov) in order to identify potentially relevant devices. Next, we searched English-language articles indexed in PubMed, Embase, and the Cochrane Database of Systematic Reviews and Database of Abstracts of Reviews of Effects through November 18, 2011, using search terms for the specific devices identified in the gray literature search, terms for signal analysis or spectral analysis, and terms for CAD, myocardial ischemia, and ACS. The exact search terms are detailed in Appendix B. The reference list of a similar review conducted in 2010^10^ was manually hand-searched and cross-checked against our library of search results, and additional citations retrieved for screening. The titles and abstracts of all citations retrieved were screened by two reviewers for potential inclusion. All citations that appeared to report primary data relevant to the study question were retrieved for full-text review.

### Inclusion and Exclusion Criteria

Titles and abstracts were screened for eligibility by two investigators and selected for full-text review if either investigator deemed the study potentially eligible. Eligibility criteria were specific to each question and are detailed in Appendix C. General eligibility criteria included:

- A relevant device must be a physical device (i.e., not simply computer software) that obtains and interprets information about the electrical activity of the heart in ways that are different from the standard 12-lead ECG.
- The device must have been approved or cleared for marketing by the U.S. FDA.
- The device must be commercially available in the United States.
- Implementation of the device in most medical facilities must be feasible.
- The device must be tested in patients at low to intermediate risk for CAD who have a clinical presentation consistent with ACS.
- The study must report relevant outcomes including performance characteristics, effects on diagnostic or treatment decisions, or effects on patient outcomes such as death, subsequent medical or surgical interventions, and health-related quality of life.

We excluded studies that reported data only from patients known to have ST elevation by standard ECG, or studies that did not report data separately for patients with and without ST elevation at the time of the initial ECG. We excluded studies that included patients under 18 years of age, if data for the patients 18 years and older were not presented separately. We also excluded studies that included a previously scheduled coronary angiogram as an eligibility criterion for patients; the rationale for this exclusion criterion is that a patient population preselected for coronary angiography is likely to include a relatively high proportion of individuals at high risk for CAD and ischemic heart disease—and as such does not represent the target population for this report.

### Data Abstraction

To aid in standardization of data collection, investigators received data abstraction instructions directly on each form created specifically for this project with the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada). We designed these forms to collect the data required to evaluate eligibility criteria for inclusion in this review, test characteristics, and effects on outcomes of interest. For eligible studies, an investigator abstracted data and assigned quality ratings. Abstracted data included first author, year of publication, study design, patient selection criteria and patient characteristics, information about the study device, reference tests used, device and reference test performance characteristics, and quality assessment ratings. A second investigator reviewed abstracted data and independently assigned quality ratings. Disagreements were resolved by consensus. Quality ratings were based on the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) tool11–13 and included characteristics of sample selection, adequate description of the index and reference tests, blinded interpretation of the index and reference tests, and presence of verification bias (Appendix D). To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of Good, Fair, and Poor based on the study’s adherence to well-accepted standard methodologies (such as QUADAS) and adequate reporting standards (Table D-1 in Appendix D).

### Data Analysis

Device performance was summarized using sensitivity, specificity, and likelihood ratios. Test sensitivity describes the proportion of subjects with disease who have an abnormal test. Test specificity describes the proportion of subjects without disease who have a normal test. A likelihood ratio is a measure that may be more useful to clinicians since a simple nomogram allows posttest disease probabilities to be readily calculated. The positive likelihood ratio (LR+) describes how many times more likely it is that an abnormal test comes from a patient with disease versus a patient without disease. The negative likelihood ratio (LR-) describes how many times more likely it is that a normal test comes from a patient with disease versus a patient without disease.

When studies were conceptually homogeneous, we used random-effects bivariate meta-analysis to compute a summary estimate of performance.14 A random-effects model assumes that variability is a result of sampling errors as well as the true differences between studies and provides a meta-analytic modeling approach for pooling sensitivity and specificity, while accounting for possible correlation between sensitivities and specificities of the studies included.15 For studies that derived a test algorithm in a training set and tested performance in a validation set, we analyzed performance characteristics from the validation set. We evaluated statistical heterogeneity by inspecting forest plots and computing Q and I^2^ statistics. Since the Q test is underpowered, we set the threshold for significant heterogeneity at p<0.10. For the I^2^ test, a suggested interpretation is to assign the terms low, moderate, and high to I^2^ values of 25 percent, 50 percent, and 75 percent, respectively.16

### Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the project to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include three progressively stricter screening opportunities for each article (abstract screening, full-text screening, and data abstraction); involvement of at least two individuals (an abstractor and a second investigator) in each data abstraction; and agreement of at least two investigators on all included studies.

Our principle external quality-monitoring device was the peer-review process. Nominations for peer reviewers were solicited from several sources, including clinical content experts from the EPC and AHRQ. The list of nominees was forwarded to AHRQ for vetting and approval. A list of peer reviewers is in the Preface of this report.