# Introduction

## Epidemiology of Coronary Artery Disease (CAD)

Cardiovascular disease remains the leading cause of mortality in the United States. An estimated one in three adults has one or more types of cardiovascular diseases, including hypertension, coronary artery disease (CAD), heart failure, stroke, and congenital defects.1 Approximately 13 million individuals in the United States have CAD. Of these, approximately 7 million have angina pectoris (chest pain) and have had a myocardial infarction (MI).1 While chest pain is a common symptom of patients presenting to clinics and emergency wards, only about 6 percent of patients presenting to the emergency room with acute chest pain are ultimately diagnosed with MI.2 Identification of which patients with chest pain are experiencing myocardial ischemia or infarction is critical since a delay in diagnosis can impede the application of effective therapies, such as thrombolytic agents or primary percutaneous coronary intervention (PCI). Tests that identify patients with significant CAD serve as a means of facilitating aggressive implementation of secondary preventive strategies. In a large national sample, only 37.6 percent of patients without known CAD referred for elective coronary angiography—most of whom had undergone prior noninvasive testing—were found to have obstructive CAD.3 Thus, accurate, noninvasive diagnostic tests and protocols are important in order to properly triage patients presenting with chest pain. Currently available tests identify a relatively low proportion of patients who will benefit from secondary prevention.

## CAD Versus Ischemia Versus Infarction

A diagnosis of CAD results from findings suggestive of atherosclerotic plaque in the coronary arteries. This plaque may or may not create an obstruction to coronary blood flow. The buildup of atherosclerotic plaque is a progressive and diffuse process that develops in the coronary arteries. Plaque formation may begin prior to middle age and may be asymptomatic, as evidenced from previous autopsy studies of young soldiers and young victims of motor vehicle accidents. CAD is believed to have a polygenetic basis, influenced by an individual’s genes as well as their susceptibility to environmental influences (such as diet and exercise). The progression and severity of CAD is associated with advancing age such that older individuals have a higher likelihood of CAD, even without the presence of other risk factors.

Patients with CAD may or may not present objective evidence of myocardial ischemia, defined as a mismatch between coronary blood flow and myocardial oxygen demand. Traditional observations have indicated that myocardial ischemic imbalance may begin to occur when the luminal narrowing of the coronary artery exceeds 70 percent. In a clinical setting, ischemia may trigger an episode of angina pectoris or other equivalent symptoms of reduced oxygen delivery to the myocardium (e.g., shortness of breath, epigastric discomfort, jaw or arm pain/heaviness). Stress tests, whether solely electrocardiographic or combined with imaging modalities, are designed to qualitatively or quantitatively identify decreased regional myocardial blood flow in the distribution of the corresponding coronary artery. Patients who exhibit ischemia on stress testing and whose symptoms are not optimally managed with medical therapy are often referred for diagnostic coronary angiography and then elective revascularization if indicated. Prolonged ischemia may result in MI, although infarction can also develop in nonobstructive coronary vessels as a consequence of a spontaneous atheromatous plaque rupture. The hallmark of infarction is elevation of cardiac muscle biomarker serum levels, including cardiac troponin and the creatine kinase MB isoenzyme. Elevation of cardiac troponin serves as evidence of myocardial cell death. Compared with patients without a prior MI, patients with a history of MI are at higher risk for future cardiac events, including recurrent infarction and death.

## Acute Coronary Syndrome (ACS)

Acute coronary syndrome (ACS) is a term commonly used to describe the clinical presentation that includes acute onset of chest pain or other symptoms that suggest myocardial ischemia or infarction. ACS typically serves as a “working diagnosis” for patients suspected of having ischemic heart disease, pending the establishment or ruling out of specific diagnoses.2

The first, and potentially most important, test typically administered in the workup of a patient with symptoms suggestive of ACS is the standard, resting 12-lead ECG. Typically, the ECG will indicate ST elevation myocardial infarction (STEMI) or be normal or nondiagnostic. If the ECG indicates STEMI, the patient will most likely be taken directly to coronary angiography, and patient outcomes would not be expected to improve with further testing. A normal or nondiagnostic ECG result does not rule out the possibility of acute ischemia or infarction, so further testing is usually indicated. Patients without ST elevation on the initial ECG who are ultimately found via further testing (e.g., elevated cardiac biomarkers, stress testing) to have undergone MI are diagnosed as having had non-ST elevation myocardial infarction (NSTEMI). Patients without ST elevation on the initial ECG who subsequently show evidence (e.g., by stress testing) of reversible myocardial ischemia are usually ascribed the diagnosis of unstable angina. Patients with the clinical presentation of acute-onset chest pain or other symptoms suggesting a cardiac etiology without ST elevation on initial ECG may continue to be considered to have ACS, pending the results of further testing.

Patients who present with symptoms suggestive of ACS and who have a nondiagnostic or normal resting ECG fall into one of two categories: (1) they are experiencing myocardial ischemia or infarction (the ECG was falsely negative) or (2) their symptoms are not caused by acute ischemic heart disease. Patients with a false-negative ECG represent the population for which improvement on diagnostic performance of the resting ECG is likely to have the greatest potential for benefit. These patients are at high risk for not receiving potentially life-saving and highly time-sensitive treatments. Patients with a false-positive ECG may also potentially benefit from a more accurate, noninvasive test than the resting ECG by avoiding the need for subsequent invasive testing or possibly harmful treatment. The potential harms associated with undiagnosed and untreated ischemic heart disease, however, are generally considered greater than the potential harms associated with further workup and treatment of patients with false-positive ECGs.

## Diagnostic Testing and Risk Stratification for CAD

CAD is an important risk factor for the development of ischemic heart disease. It follows, therefore, that risk stratification for the presence of CAD may help improve both the accuracy of diagnosis and the timely treatment of ischemic heart disease among patients with ACS. Figure 1 illustrates the relationship between risk stratification and clinical decisionmaking for patients without known CAD who present with chest pain or other symptoms for which CAD-related myocardial ischemia is a possible etiology. Tests designed to diagnose CAD may not be indicated in patients who are deemed to be at very low risk, such as in the case of a healthy 22-year-old woman with atypical chest pain and no known risk factors for CAD. Similarly, a 73-year-old man with diabetes, hypertension, and a long history of tobacco use who presents with exertional substernal chest pain is likely to be treated initially for presumptive myocardial ischemia without confirmatory testing for CAD. In neither scenario would diagnostic testing be expected to move a patient across decisionmaking thresholds (indicated by the letters A and B in Figure 1).

Figure 1 Decision threshold conceptual model

Abbreviation: CAD=coronary artery disease

Noninvasive diagnostic testing may, however, be particularly informative for the large population of patients who are best categorized as having a low to intermediate risk for CAD, yet who present with chest pain or other symptoms suggestive of ACS. For this category of patients, represented by the space between A and B in Figure 1, noninvasive test results have proven useful for posttest decisionmaking.4 Within this framework of pretest risk prediction, decisions regarding which diagnostic test to use—or the decision not to perform a test at all—must be made.

Recently published guidelines5 propose three diagnostic classifications of patients who present with symptoms suggestive of ACS, based on findings from an initial resting ECG: (1) STEMI (including patients with presumed new left bundle branch block), (2) unstable angina or NSTEMI, and (3) nondiagnostic ECG. For the purpose of this report, we considered patients with STEMI or STEMI-equivalent (defined as ST depression occurring in precordial leads V_1_–V_4_, indicating ST elevation on the left ventricular posterior wall opposite to the interventricular septum) to be at high risk for both CAD and ischemic heart disease. The target population for the purpose of this report excludes these high-risk patients and focuses, rather, on patients with symptoms suggestive of ACS at low to intermediate risk for CAD, including patients with a clinical presentation and initial ECG findings consistent with unstable angina or NSTEMI as well as patients with a nondiagnostic resting ECG at time of presentation.

## Role and Limitations of ECG in the Diagnostic Workup of CAD and ACS

In patients where CAD or ACS is suspected—either because of the presence of risk factors for CAD or because of symptoms that may represent manifestations of CAD (e.g., chest pain)—the standard ECG is one of the most commonly performed tests.6 By providing a “snapshot” of the heart’s electrocardiographic activity, the ECG allows the reading physician to assess the signs suggestive of acute ischemia, hypertrophy, arrhythmia, history of MI, or the risk of inherited cardiomyopathies such as long-QT syndrome or Wolff-Parkinson-White syndrome. The ECG is nearly universally available and is noninvasive, easy to perform, relatively inexpensive, and expedient (an ECG can usually be performed in less than 5 minutes). Also, most ECG machines are equipped with computerized diagnostic algorithms that provide an immediate preliminary interpretation, which is made available for physician review.

However, the standard ECG has several significant limitations. First, an ECG represents electrocardiographic activity at a single moment in time while the patient is at rest. As such, ECGs often need to be repeated as a patient’s clinical condition changes. Second, although wave-pattern recognition and comparison with expected normal findings are used in ECG assessment, the final analysis is open to subjective interpretation by the reading physician. Finally, a resting ECG’s diagnostic utility is severely limited in the diagnosis of CAD, with an estimated sensitivity between 12 and 70 percent depending on the population studied and criteria applied.7,8 Nevertheless, despite its limited utility in the diagnosis of CAD, the standard ECG is perhaps the single most useful test in the initial evaluation of a patient with ACS because it can rapidly identify patients who are likely to be experiencing acute myocardial ischemia.

## Evaluating Emerging ECG-based Technologies

New devices that seek to improve ECG capabilities in the evaluation of patients with chest pain have been proposed—specifically, devices that are potentially capable of detecting myocardial ischemia or identifying patients who may have significant CAD, myocardial ischemia, or MI. An enhanced ECG-based test might demonstrate greater positive or negative predictive values, thereby limiting the harms associated with delays in treatment (as in the example of a posterior MI that was not evident on the 12-lead ECG), or by providing the diagnostic information necessary to avoid invasive diagnostic or therapeutic interventions. Access to an enhanced ECG-based test—if proven to be more accurate than the standard 12-lead ECG—might also impact decisionmaking of health care providers at institutions that do not have onsite cardiac catheterization facilities.

Ideally, all new tests would be compared to the reference standard that most accurately discriminates between individuals with and without disease. Additionally, the relative advantages of a new test should be evaluated in comparison with existing technology. For example, in patients with low to intermediate risk for CAD who present with symptoms suggestive of ACS, an enhanced test might serve as a better initial diagnostic instrument than a standard ECG alone. Enhanced ECG technology could be used instead of, or in addition to, the standard 12-lead ECG. Regardless of whether a new test is intended to complement or replace the standard ECG, the performance characteristics of both technologies should be evaluated relative to one or more appropriate reference standards.

## Objectives of This Report

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Duke Evidence-based Practice Center (Contract No. HHSA 290-2007-10066-I). The purpose of this technology assessment is to summarize the clinical and scientific evidence for commercially available ECG-based signal analysis technologies used to evaluate patients with chest pain at low to intermediate risk for CAD, or with a clinical presentation consistent with ACS. This report does not address the use of these technologies to evaluate patients at high risk for CAD—defined for the purpose of this report as generally meeting accepted criteria for STEMI.

We did a gray literature search to identify emerging technologies that noninvasively analyze electrical signals from the heart, which we have collectively termed “ECG-based signal analysis technologies.” One example of such a technology is the signal-averaged ECG, which analyzes the ECG by computing the average of numerous ECG complexes. Signal averaging increases the signal-to-noise ratio, allowing for the detection of small, microvolt signals. This technique is most often used in the detection of low amplitude signals at the terminal portion of the QRS complex (also known as ventricular late potentials). Late potentials may reflect inflammation, edema, fibrosis, or infarct.

Another example of ECG-based signal analysis technology is body surface mapping (BSM), also called body surface potential mapping, which uses up to 120 ECG electrodes to expand the measured area of electrocardiographic activity. Data collected by these electrodes are used to construct a three-dimensional representation of the thorax. A more recent form of ECG-based signal analysis uses mathematical modeling to derive clinical indices. These indices are then compared with an empirical database to generate differential diagnoses and a heart disease severity score. Some ECG-based signal analysis technologies have been used for purposes other than detecting CAD, but these uses are not the focus of the current report. For example, we specifically excluded the use of ECG-based signal analysis technologies for measuring heart rate variability or tests aimed at predicting malignant arrhythmias. This report focuses on commercially available ECG-based signal analysis devices to inform AHRQ and CMS about the utility of these emerging technologies for the diagnosis and management of individuals at low to intermediate risk for CAD who present with acute-onset chest pain or other symptoms suggestive of ACS.