# Discussion

## Summary of Findings

The combined gray and published literature searches identified 11 commercially available ECG-based devices used or proposed to be used to diagnose CAD or to detect ACS. Of these, 8 are FDA cleared for marketing. Our search of the English-language literature identified 11 studies represented by 14 articles that reported on performance characteristics of one BSM device (PRIME ECG) and one signal averaging ECG device (LP 3000) in patients at low to intermediate risk for CAD who presented with chest pain or other symptoms suggestive of ACS.

The PRIME ECG has been evaluated in 10 studies by 3 different groups of investigators. Seven of these studies enrolled subjects that may have been at higher risk than the target population for this report, and nine compared the PRIME ECG to an incomplete reference standard that detects only acute myocardial injury. A single large, good-quality study50,51 estimated the sensitivity and specificity of the PRIME ECG in the diagnosis of MI and ACS in patients at low to intermediate risk for CAD who presented with symptoms suggestive of ACS.

The available published evidence suggests that the PRIME ECG device may demonstrate higher sensitivity than the standard 12-lead ECG for identifying patients with ischemic-type chest pain, with myocardial injury as assessed by biomarkers as the reference standard. The 95-percent confidence interval of the estimates of sensitivity for these two tests overlaps, such that the observed differences are not statistically significant. The magnitude of the difference in sensitivity (68% for the PRIME ECG versus 41% for the standard ECG) is, however, likely to be clinically significant. These findings do not provide compelling evidence of a real difference in test performance for these two tests, but it is possible that study heterogeneity or small sample sizes, or both, contribute to the wide and overlapping 95 percent confidence intervals, thereby obscuring a real difference that could be clinically meaningful. There does not, however, appear to be a real difference in specificity between the two tests.

The OCCULT MI trial demonstrated that, among patients with symptoms suspicious for ACS who did not present with STEMI, the PRIME ECG provided a significant increase over the 12-lead ECG for MI or ACS, but the specificity was lower and there was no difference between the two tests in the negative or positive likelihood ratios. The authors concluded that the PRIME ECG provides early risk stratification information that identifies patients at high risk for MI, ACS, and adverse clinical outcomes. Our search identified a single eligible study for the LP 3000 signal averaging ECG that suggested this device demonstrates better sensitivity than the resting 12-lead ECG in identifying which patients with acute chest pain have underlying CAD.

## Applicability of Current Studies

Eight of the eleven studies included in this report had potentially significant limitations that may affect the applicability of the findings to the target population of patients at low to intermediate risk for CAD who present for medical care with symptoms suggestive of ACS. Six studies were conducted exclusively in Ireland40–45,47,49 among a population that included patients treated in a mobile cardiac care unit, which suggests a patient population at higher risk, on average, than patients at low to intermediate risk who present to outpatient or emergency facilities in the United States. Furthermore, the PRIME ECG algorithm appears to have evolved over the 10-year span of these articles, thereby limiting the applicability of the findings from the earlier studies. Two other studies also were conducted in European countries (England46 and Greece18) in settings or among patient populations that may not be equivalent to those typically found in the United States. The remaining three studies39,48,50,51 have the highest applicability because they included patients recruited in the United States and included patients who represent the target population for the purpose of this report.

## Strengths and Limitations of This Review

The strength of our search strategy was a gray literature search to identify relevant devices. Intentionally, we did not use electronic search filtering in our searches of the gray literature, given that filters often inadvertently exclude relevant studies. The limitations of our search strategy were (1) an absence of standardized, widely accepted, reliable, and validated methods for searching the gray literature, (2) that some of the pertinent evidence was proprietary and not accessible via manufacturers’ Web sites and that we did not request information from manufacturers directly, and (3) that, in general, identifying test accuracy studies is more difficult than identifying studies of therapeutic interventions.

We relied primarily on published studies to identify evidence for potentially relevant devices. Peer-reviewed publications, however, do not always include complete information about investigational devices or methods. We therefore had difficulty tracking the lineage of both the devices and the proprietary data transformation algorithms that are central to signal analysis technologies. We do not know if the devices or the mathematical algorithms underlying the technology have remained constant over time. This problem may be common to formal evaluations of medical devices for which potentially significant changes over time are not documented in the public record.

## Future Research

Bossuyt and colleagues have proposed a framework for new test evaluation that may help guide future research pertaining to ECG-based signal averaging technologies.57 This framework considers new diagnostic tests as either potential replacement, triage, or add-on tests. Bossuyt argues that in order to determine if a new test can replace an existing one, the diagnostic accuracy of both tests needs to be compared in the same patient sample since the sensitivity and specificity of a test can vary across subgroups. Furthermore, the new tests should be compared to existing tests using the same reference standard. Most of the studies included in this report employed this study design. With the exception of the OCCULT MI trial, which used study-adjudicated diagnosis informed by several different sources, however, none of the studies used a fully adequate reference test. Elevated biomarkers alone serve as an incomplete reference standard and cannot readily differentiate acute MI from reversible ischemia. Similarly, coronary angiography, which was used as the reference standard in two of the included studies, is considered the criterion standard for CAD but cannot by itself identify patients with acute ischemic heart disease.

Replication of the OCCULT MI study potentially could provide important information about the relative value of an ECG-based signal analysis device relative to the standard ECG to inform decisionmaking and improve patient outcomes among patients with ACS. The OCCULT MI study demonstrated that that among patients who were not ultimately diagnosed as having STEMI, ST elevation detected by the PRIME ECG was associated with increased mortality, whereas ST elevation on a standard 12-lead ECG was not predictive of adverse outcomes in this sample of patients. There are at least two interpretations of these findings: (1) the PRIME ECG correctly identified patients that had a false-negative ECG, or (2) a positive test result on the PRIME ECG may influence clinical decisionmaking in a way that results in harm, relative to the standard ECG. Further study is needed to confirm or investigate this finding, and more research along these lines may provide useful information about the tradeoff between improving the false-negative rate of resting ECG versus initiating further testing or treatment for patients with ACS who have a normal (or nondiagnostic) ECG test result and a positive test result on a body surface mapping device.

Other lines of research could evaluate patients and settings where ECG-based signal analysis technology might be most beneficial, or could investigate whether an ECG-based signal analysis device could serve to complement the findings from standard 12-lead ECGs as “add-on” tests. Add-on tests could be used in a subgroup of patients where diagnosis needs clarification. For example, add-on tests could be used to further evaluate a patient who presents with a normal ECG but who nonetheless is having active chest pain. An add-on test may be able to help clarify whether such a patient is having chest pain due to cardiac etiologies that are undetected by the 12-lead ECG, or chest pain due to a noncardiac cause. Add-on tests are attractive because they offer noninvasive, accurate alternatives to the standard 12-lead ECG. However, add-on tests are less attractive in that they are more expensive, more time consuming for medical personnel, and currently have limited availability in clinical settings. The add-on test strategy can potentially increase the sensitivity of the existing testing standards—but possibly at the expense of specificity. Study designs that are more efficient than the fully paired evaluation could be used to evaluate this add-on strategy. The OCCULT MI study may serve as a good example of this type of study.

The available published literature on ECG-based signal analysis technologies does not provide answers to the key questions surrounding debate about whether these technologies have an impact on diagnostic decisionmaking or patient outcomes. However, these questions may best be addressed by RCTs. Depending on the specific question, a number of trial designs could be considered, including a clinical trial of test-positive patients, with clinicians randomized to disclosure of test results. Another alternative would be a trial that randomizes patients to a test strategy using conventional testing versus one that uses a new device. Finally, a less direct approach would be to link evidence on test performance to evidence on the effects of interventions (e.g., antianginals or percutaneous coronary intervention) in the population of interest. This final example is sometimes employed by the U.S. Preventive Services Task Force for evaluating screening tests. This less direct approach is more subject to bias due to the underlying assumptions that are inherent in creating such linkages.

To date, the existing literature among the target population for this report is limited to 10 studies of one body surface mapping device and 1 study of a signal averaging device. Additional research is needed to evaluate the utility of other ECG-based signal analysis devices among patients at low to intermediate risk of CAD in the evaluation of ACS or among subgroups of patients. ECG-based signal analysis devices might, for example, provide new and useful information for patients with left bundle branch block or other physiological processes that interfere with the ability of the standard ECG to detect acute ischemic heart disease. Patients who have a nondiagnostic or normal ECG at presentation but whose clinical presentation is suggestive of ischemic heart disease constitute an especially vulnerable population that may benefit from an add-on ECG-based test. Future research is needed to evaluate the role of ECG-based signal analysis devices for improving the ability of noninvasive, easily and quickly administered bedside tests to identify which patients are appropriate candidates for urgent treatment or further treatment.