# Summary and Conclusions

Currently, a paucity of evidence exists about the utility of ECG-based signal analysis technologies as a diagnostic test among patients at low to intermediate risk for CAD who present in the outpatient setting with the chief complaint of chest pain or with symptoms suggestive of ACS. Most devices identified by our gray literature search did not appear to have published articles describing their performance among the target population for this report. The literature was not sufficient to determine if factors such as sex, body habitus, medications, and comorbid medical conditions affected test performance.

The limited available evidence demonstrates proof of concept, particularly for the PRIME ECG device, and it suggests that the sensitivity of BSM and signal averaging devices is higher compared with standard ECG for identifying patients with ACS who have either ischemic heart disease or CAD. However, this evidence is limited by the use of incomplete reference standards in the published studies, including elevated biomarkers for detecting acute ischemic heart disease.

Further research is needed to better describe the performance characteristics of these devices to determine in what circumstances, if any, these devices might precede, replace, or add to the standard ECG in test strategies to identify patients with clinically significant CAD in the patient population of interest. To fully assess the impact of these devices on the diagnostic strategies for patients with chest pain, test performance needs to be linked to clinically important outcomes through modeling or longitudinal studies.