# Excluded Studies

All studies listed below were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Abboud S. High-frequency electrocardiogram analysis of the entire QRS in the diagnosis and assessment of coronary artery disease. Prog Cardiovasc Dis. 1993;35(5):311-328. [pmid: 8456174]. Exclude - Does not present original data
Abboud S, Belhassen B, Miller HI, et al. High frequency electrocardiography using an advanced method of signal averaging for non-invasive detection of coronary artery disease in patients with normal conventional electrocardiogram. J Electrocardiol. 1986;19(4):371-380. [pmid: 3794576]. Exclude - Does not include a relevant device
Abboud S, Berenfeld O, Sadeh D. Simulation of high-resolution QRS complex using a ventricular model with a fractal conduction system. Effects of ischemia on high-frequency QRS potentials. Circ Res. 1991;68(6):1751-1760. [pmid: 2036723]. Exclude - Does not present original data
Abboud S, Cohen RJ, Selwyn A, et al. Detection of transient myocardial ischemia by computer analysis of standard and signal-averaged high-frequency electrocardiograms in patients undergoing percutaneous transluminal coronary angioplasty. Circulation. 1987;76(3):585-596. [pmid: 2957111]. Exclude - Does not include a relevant device
Abboud S, Zlochiver S. High-frequency QRS electrocardiogram for diagnosing and monitoring ischemic heart disease. J Electrocardiol. 2006;39(1):82-86. [pmid: 16387057]. Exclude - Does not present original data
Abildskov JA, Green LS, Lux RL. The present status of body surface potential mapping. J Am Coll Cardiol. 1983;2(2):394-396. [pmid: 6863774]. Exclude - Does not present original data
Ackaoui A, Nadeau R, Sestier F, et al. Myocardial infarction diagnosis with body surface potential mapping, electrocardiography, vectorcardiography and thallium-201 scintigraphy: a correlative study with left ventriculography. Clin Invest Med. 1985;8(1):68-77. [pmid: 3987121]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Adam D, Gilat S. Classification of pathologies by reduced sequential potential maps. Med Biol Eng Comput. 1992;30(1):26-31. [pmid: 1640751]. Exclude - Does not present data specific to patients 18 yrs of age or older
Afsar FA, Arif M, Yang J. Detection of ST segment deviation episodes in ECG using KLT with an ensemble neural classifier. Physiol Meas. 2008;29(7):747-760. [pmid: 18560057]. Exclude - Does not include a relevant device
Agarwal M, Mehta PK, Bairey Merz CN. Nonacute coronary syndrome anginal chest pain. Med Clin North Am. 2010;94(2):201-216. [pmid: 20380951]. Exclude - Does not present original data
Agetsuma H, Suzuki A, Hirai M, et al. Evaluation of QRST isointegral maps in detecting posterior myocardial infarction with and without conduction disturbance. Clin Cardiol. 1995;18(2):73-79. [pmid: 7720293]. Exclude - Does not include a relevant device
Ammar KA, Kors JA, Yawn BP, et al. Defining unrecognized myocardial infarction: a call for standardized electrocardiographic diagnostic criteria. Am Heart J. 2004;148(2):277-284. [pmid: 15308997]. Exclude - Does not present original data
Andersen K, Eriksson P, Dellborg M. Non-invasive risk stratification within 48 h of hospital admission in patients with unstable coronary disease. Eur Heart J. 1997;18(5):780-788. [pmid: 9152648]. Exclude - Does not include a relevant device
Andersen MP, Terkelsen CJ, Struijk JJ. The ST Compass: spatial visualization of ST-segment deviations and estimation of the ST injury vector. J Electrocardiol. 2009;42(2):181-189. [pmid: 19159903]. Exclude - Does not include a relevant device
Anonymous. ST-segment distortion in manual report mode of electrocardiographs. Health Devices. 1995;24(8–9):362-363. [pmid: 8530307]. Exclude - Not a full peer-reviewed publication
Astrom M, Garcia J, Laguna P, et al. Detection of body position changes using the surface electrocardiogram. Med Biol Eng Comput. 2003;41(2):164-171. [pmid: 12691436]. Exclude - Does not include a relevant device
Aufderheide TP, Rowlandson I, Lawrence SW, et al. Test of the acute cardiac ischemia time-insensitive predictive instrument (ACI-TIPI) for prehospital use. Ann Emerg Med. 1996;27(2):193-198. [pmid: 8629751]. Exclude - Does not include a relevant device
Bacharova L, Mateasik A, Carnicky J, et al. The Dipolar ElectroCARdioTOpographic (DECARTO)-like method for graphic presentation of location and extent of area at risk estimated from ST-segment deviations in patients with acute myocardial infarction. J Electrocardiol. 2009;42(2):172-180. [pmid: 19159899]. Exclude - Does not include a relevant device
Bahr RD. Body Surface Mapping. Potential Role in a Chest Pain Critical Care Pathway: Commentary. Crit Pathw Cardiol. 2003;2(1):52-53. [pmid: 18340319]. Exclude - Does not present original data
Bakul G, Tiwary US. Automated risk identification of myocardial infarction using relative frequency band coefficient (RFBC) features from ECG. Open Biomed Eng J. 2010;4(SPEC. ISSUE 2):217-222. [pmid: 21625645]. Exclude - Does not include a relevant device
Bauernfeind T, Preda I, Szakolczai K, et al. Diagnostic value of the left atrial electrical potentials detected by body surface potential mapping in the prediction of coronary artery disease. Int J Cardiol. 2011;150(3):315-318. [pmid: 20537737]. Exclude - Does not include a relevant device
Beauregard LA, Volosin KJ, Askenase AD, et al. Effects of exercise on signal-averaged electrocardiogram. Pacing Clin Electrophysiol. 1996;19(2):215-221. [pmid: 8834691]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Beker A, Pinchas A, Erel J, et al. Analysis of high frequency QRS potential during exercise testing in patients with coronary artery disease and in healthy subjects. Pacing Clin Electrophysiol. 1996;19(12 Pt 1):2040-2050. [pmid: 8994942]. Exclude - Does not include a relevant device
Bell AJ, Briggs CM, Nichols P, et al. Relationship of ST-segment elevation to eventual QRS loss in acute anterior wall myocardial infarction. J Electrocardiol. 1993;26(3):177-185. [pmid: 8409812]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Bell AJ, Loughhead MG, Walker SJ, et al. Prognostic significance of ST potentials determined by body surface mapping in inferior wall acute myocardial infarction. Am J Cardiol. 1989;64(5):319-323. [pmid: 2756875]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Bell AJ, Walker SJ, Kilpatrick D. Natural history of ST-segment potential distribution determined by body surface mapping in patients with acute inferior infarction. J Electrocardiol. 1989;22(4):333-341. [pmid: 2794835]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Berkalp B, Baykal E, Caglar N, et al. Analysis of high frequency QRS potentials observed during acute myocardial infarction. Int J Cardiol. 1993;42(2):147-153. [pmid: 8112919]. Exclude - Does not include a relevant device
Bigger JT Jr, Hoover CA, Steinman RC, et al. Autonomic nervous system activity during myocardial ischemia in man estimated by power spectral analysis of heart period variability. The Multicenter Study of Silent Myocardial Ischemia Investigators. Am J Cardiol. 1990;66(4):497-498. [pmid: 2201185]. Exclude - Does not include a relevant device
Bigi MAB, Aslani A. SAECG in exercise test for prediction of diabetic coronary artery disease. Central European Journal of Medicine. 2010;5(3):298-302. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Birnbaum Y, Wagner GS. The initial electrocardiographic pattern in acute myocardial infarction: correlation with infarct size. J Electrocardiol. Suppl. 1999;32:122-128. [pmid: 10688315]. Exclude - Does not include a relevant device
Bjerle P, Niklasson U. Comparison between three different stand-alone ECG interpretation systems. J Electrocardiol. Suppl. 1988;21:S163-S168. [pmid: 3063769]. Exclude - Does not include a relevant device
Block P, Eeckhout E, Convents K, et al. Analysis of the cumulative RMS amplitude curve of the signal-averaged ECG in the subacute stage of myocardial infarction. J Electrocardiol. Suppl. 1992;24:195-196. [pmid: 1552256]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Bojovic B, Hadzievski L, Vukcevic VD, et al. Visual 3Dx: algorithms for quantitative 3-dimensional analysis of ECG signals. Conference Proceedings: Annual International Conference of the IEEE Engineering in Medicine & Biology Society. IEEE Eng Med Biol Mag. 2009:6751-6754. Exclude - Does not include a relevant device
Bond RR, Finlay DD, Nugent CD, et al. XML-BSPM: an XML format for storing Body Surface Potential Map recordings. BMC Med Inform Decis Mak. 2010;10:28. [pmid: 20470392]. Exclude - Does not include a relevant device
Borbola J, Denes P. Short- and long-term reproducibility of the signal-averaged electrocardiogram in coronary artery disease. Am J Cardiol. 1988;61(13):1123-1124. [pmid: 3364369]. Exclude - Does not include a relevant device
Boudik F, Stojan M, Anger Z, et al. Evaluation of body surface potential mapping changes after successful percutaneous transluminal coronary angioplasty. Can J Cardiol. 1996;12(8):745-749. [pmid: 8794778]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Brady WJ. Taking cardiac imaging to new dimensions: Body surface mapping. Consultant. 2006;46(13):1450-1457. Exclude - Not a full peer-reviewed publication
Brady WJ. The Earth is flat! The electrocardiogram has 12 leads! The electrocardiogram in the patient with ACS: looking beyond the 12-lead electrocardiogram. Am J Emerg Med. 2007;25(9):1073-1076. [pmid: 18022504]. Exclude - Does not present original data
Breithardt G, Borggrefe M, Martinez-Rubio A. Signal averaging. Ann N Y Acad Sci. 1990;601:180-196. [pmid: 2221685]. Exclude - Does not present original data
Breithardt G, Wichter T, Fetsch T, et al. The signal-averaged ECG: time-domain analysis. Eur Heart J. Suppl E. 1993;14:27-32. [pmid: 8223752]. Exclude - Does not present original data
Bruce RA, Fisher LD, Pettinger M, et al. ST segment elevation with exercise: a marker for poor ventricular function and poor prognosis. Coronary Artery Surgery Study (CASS) confirmation of Seattle Heart Watch results. Circulation. 1988;77(4):897-905. [pmid: 3349585]. Exclude - Does not include a relevant device
Budnyk MM, Kozlovsky VI, Stadnyuk LA, et al. Evaluation of magnetocardiography indices in patients with cardiac diseases. Neurol Clin Neurophysiol. 2004;2004:111. [pmid: 16012664]. Exclude - Does not include a relevant device
Burattini L, Zareba W. Time-domain analysis of beat-to-beat variability of repolarization morphology in patients with ischemic cardiomyopathy. J Electrocardiol. Suppl. 1999;32:166-172. [pmid: 10688321]. Exclude - Not a full peer-reviewed publication
Burattini L, Zareba W, Rashba EJ, et al. ECG features of microvolt T-wave alternans in coronary artery disease and long QT syndrome patients. J Electrocardiol. Suppl. 1998;31:114-120. [pmid: 9988014]. Exclude - Does not include a relevant device
Cahyadi YH, Murakami E, Takekoshi N, et al. Body surface potential mapping in anterior myocardial infarction--a longitudinal study in acute, convalescent and chronic phases. Jpn Circ J. 1989;53(3):206-212. [pmid: 2787417]. Exclude - Does not include a relevant device
Cahyadi YH, Takekoshi N, Matsui S. Clinical efficacy of PTCA and identification of restenosis: evaluation by serial body surface potential mapping. Am Heart J. 1991;121(4 Pt 1):1080-1087. [pmid: 2008829]. Exclude - Does not include a relevant device
Cairns CB, Niemann JT, Selker HP, et al. Computerized version of the time-insensitive predictive instrument. Use of the Q wave, ST-segment, T wave, and patient history in the diagnosis of acute myocardial infarction by the computerized ECG. J Electrocardiol. Suppl. 1992;24:46-49. [pmid: 1552267]. Exclude - Does not include a relevant device
Can L, Kayikcioglu M, Evrengul H, et al. Serial analyses of ventricular late potentials in patients with reciprocal ST segment changes during acute myocardial infarction. Jpn Heart J. 2003;44(1):1-10. [pmid: 12622432]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Cantor A, Goldfarb B, Aszodi A, et al. QRS prolongation measured by a new computerized method: a sensitive marker for detecting exercise-induced ischemia. Cardiology. 1997;88(5):446-452. [pmid: 9286507]. Exclude - Does not include a relevant device
Cantor A, Goldfarb B, Aszodi A, et al. Ischemia detection after myocardial infarction: diagnostic value of exercise-induced QRS duration changes evaluated by a new computerized method. J Electrocardiol. 1998;31(1):9-15. [pmid: 9533373]. Exclude - Does not include a relevant device
Caref EB, Goldberg N, Mendelson L, et al. Effects of exercise on the signal-averaged electrocardiogram in coronary artery disease. Am J Cardiol. 1990;66(1):54-58. [pmid: 2360534]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Carley S, Mackway-Jones K, Jenkins M, et al. A novel method for the detection of transient myocardial ischaemia using body surface electrocardiac mapping. Int J Cardiol. 2004;95(1):75-81. [pmid: 15159042]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Carley SD. Beyond the 12 lead: review of the use of additional leads for the early electrocardiographic diagnosis of acute myocardial infarction. Emerg Med (Fremantle). 2003;15(2):143-154. [pmid: 12675624]. Exclude - Does not present original data
Carley SD, Mackway-Jones K, Curzen N. Detection of evolving right ventricular infarct during right coronary artery stent insertion using PRIME ECG body surface mapping with colour map reconstruction. Resuscitation. 2004;61(3):361-364. [pmid: 15172717]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Carpeggiani C, Emdin M, Raciti M, et al. Heart rate variability and myocardial infarction: acute and subacute phase. CNR-PF FATMA Multicenter Study on psycho-neurological risk factors in acute myocardial infarction. Clin Sci (Lond). Suppl. 1996;91:28-29. [pmid: 8813820]. Exclude - Does not include a relevant device
Casolo G, Balli E, Fazi A, et al. Twenty-four-hour spectral analysis of heart rate variability in congestive heart failure secondary to coronary artery disease. Am J Cardiol. 1991;67(13):1154-1158. [pmid: 1809257]. Exclude - Does not include a relevant device
Celik T, Iyisoy A, Isik E, et al. Surface electrocardiography and biochemical variables in patients with coronary artery disease: the ugly face of microalbuminuria. Int J Cardiol. 2008;128(3):430-431. [pmid: 17673318]. Exclude - Not a full peer-reviewed publication
Chandrasekaran S, Hochman JS, Slater JN, et al. Relation between infarct artery patency at late angiography after acute myocardial infarction and signal-averaged electrocardiography. Am J Cardiol. 1999;84(6):734-736. A8. [pmid: 10498147]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Chen J, Thomson PD, Nolan V, et al. Age and sex dependent variations in the normal magnetocardiogram compared with changes associated with ischemia. Ann Biomed Eng. 2004;32(8):1088-1099. [pmid: 15446505]. Exclude - Does not include a relevant device
Cohen D, Savard P, Rifkin RD. Magnetic measurements of S-T and T-Q segment shifts in humans. Part II: Exercise-induced S-T segment depression. Circ Res. 1983;53(2):274-279. [pmid: 6883650]. Exclude - Does not include a relevant device
Collins MS, Carter JE, Dougherty JM, et al. Hyperacute T-wave criteria using computer ECG analysis. Ann Emerg Med. 1990;19(2):114-120. [pmid: 2301787]. Exclude - Does not include a relevant device
Cripps T, Bennett D, Camm J, et al. Prospective evaluation of clinical assessment, exercise testing and signal-averaged electrocardiogram in predicting outcome after acute myocardial infarction. Am J Cardiol. 1988;62(16):995-999. [pmid: 3189192]. Exclude - Does not include a relevant device
Daly MJ, Harbinson MT, Adgey AJ. Body surface potential mapping improves diagnosis of ST-elevation myocardial infarction in patients with significant left main coronary artery stenosis presenting with acute chest pain. Eur Heart J. 2011;32:1058. Exclude - Not a full peer-reviewed publication
Daly MJ, McCann CJ, Owens CG, et al. Heart fatty acid-binding protein in combination with the 80-lead body surface potential map improves early detection of acute myocardial infarction in patients who are cardiac troponin T-negative at presentation. J Electrocardiol. 2011;44(4):432-438. [pmid: 21529821]. Exclude - Study does not address target population, or does not address diagnosing CAD, ischemia or ACS
Dawoud F, Wagner GS, Moody G, et al. Using inverse electrocardiography to image myocardial infarction--reflecting on the 2007 PhysioNet/Computers in Cardiology Challenge. J Electrocardiol. 2008;41(6):630-635. [pmid: 18954610]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
De Ambroggi L, Bertoni T, Breghi ML, et al. Diagnostic value of body surface potential mapping in old anterior non-Q myocardial infarction. J Electrocardiol. 1988;21(4):321-329. [pmid: 3241143]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
de Chillou C, Doevendans P, Cheriex E, et al. Echocardiographic wall motion abnormalities and the signal averaged electrocardiogram in the acute phase of a first myocardial infarction. Eur Heart J. 1993;14(6):795-798. [pmid: 8325307]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
de Chillou C, Rodriguez LM, Doevendans P, et al. Effects on the signal-averaged electrocardiogram of opening the coronary artery by thrombolytic therapy or percutaneous transluminal coronary angioplasty during acute myocardial infarction. Am J Cardiol. 1993;71(10):805-809. [pmid: 8456758]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
de Chillou C, Rodriguez LM, Doevendans P, et al. Factors influencing changes in the signal-averaged electrocardiogram within the first year after a first myocardial infarction. Am Heart J. 1994;128(2):263-270. [pmid: 8037092]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Degre SG, Fang ZY, Sobolski J, et al. Detection of silent myocardial ischemia in asymptomatic selected population and in unstable angina. Adv Cardiol. 1990;37:215-222. [pmid: 2120910]. Exclude - Does not include a relevant device
Dehnavi ARM, Farahabadi I, Rabbani H, et al. Detection and classification of cardiac ischemia using vector cardiogram signal via neural network. J Res Med Sci. 2011;16(2). Exclude - Does not include a relevant device
Delgado-Trejos E, Perera-Lluna A, Vallverdu-Ferrer M, et al. Dimensionality reduction oriented toward the feature visualization for ischemia detection. IEEE Trans Inf Technol Biomed. 2009;13(4):590-598. [pmid: 19304491]. Exclude - Does not include a relevant device
Dellborg M, Steg PG, Simoons M, et al. Increased rate of evolution of QRS changes in patients with acute myocardial infarction. Results from the Vermut Study. J Electrocardiol. Suppl. 1993;26:244-248. [pmid: 8189132]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Doniwa K, Kawaguchi T, Okajima M. Body surface potential mapping--its application to animal experiments and clinical examinations. Med Prog Technol. 1987;12(1–2):117-122. [pmid: 3627015]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Donnelly MP, Nugent CD, Finlay DD, et al. Diagnosing old MI by searching for a linear boundary in the space of principal components. IEEE Trans Inf Technol Biomed. 2006;10(3):476-483. [pmid: 16871714]. Exclude - Does not include a relevant device
Dori G, Denekamp Y, Fishman S, et al. Non-invasive computerised detection of acute coronary occlusion. Med Biol Eng Comput. 2004;42(3):294-302. [pmid: 15191073]. Exclude - Does not include a relevant device
Douglas PK, Batdorf NJ, Evans RT, et al. Temporal and postural variation of 12-lead high-frequency QRS electrocardiographic signals in asymptomatic individuals. J Electrocardiol. 2006;39(3):259-265. [pmid: 16777512]. Exclude - Does not include a relevant device
Dranca L, Goni A, Illarramendi A. Real-time detection of transient cardiac ischemic episodes from ECG signals. Physiol Meas. 2009;30(9):983-998. [pmid: 19696464]. Exclude - Does not include a relevant device
Drew BJ, Pelter MM, Wung SF, et al. Accuracy of the EASI 12-lead electrocardiogram compared to the standard 12-lead electrocardiogram for diagnosing multiple cardiac abnormalities. J Electrocardiol. Suppl. 1999;32:38-47. [pmid: 10688301]. Exclude - Does not include a relevant device
Drew BJ, Schindler DM, Zegre JK, et al. Estimated body surface potential maps in emergency department patients with unrecognized transient myocardial ischemia. J Electrocardiol. 2007;40(6 Suppl):S15-S20. [pmid: 17993313]. Exclude - Does not include a relevant device
Drew BJ, Wung SF, Adams MG, et al. Bedside diagnosis of myocardial ischemia with ST-segment monitoring technology: measurement issues for real-time clinical decision making and trial designs. J Electrocardiol. Suppl. 1998;30:157-165. [pmid: 9535494]. Exclude - Does not include a relevant device
Dunbar DN, Denes P. Operational aspects of signal-averaged electrocardiography. Prog Cardiovasc Dis. 1993;35(5):329-348. [pmid: 8456175]. Exclude - Does not present original data
Edenbrandt L, Pahlm O, Lyttkens K, et al. Improved ECG interpretation using synthesized VCG for the diagnosis of inferior myocardial infarction. J Electrocardiol. 1990;23(3):207-211. [pmid: 2384726]. Exclude - Does not include a relevant device
Eisenstein I, Sanmarco ME, Madrid WL, et al. Electrocardiographic and vectorcardiographic diagnosis of posterior wall myocardial infarction. Significance of the T wave. Chest. 1985;88(3):409-416. [pmid: 4028851]. Exclude - Does not include a relevant device
el-Sherif N, Mehra R, Restivo M. Beat-to-beat high-resolution electrocardiogram: technical and clinical aspects. Prog Cardiovasc Dis. 1993;35(6):407-415. [pmid: 8497656]. Exclude - Does not include a relevant device
Emmot W, Vacek JL. Lack of reproducibility of frequency versus time domain signal-averaged electrocardiographic analyses and effects of lead polarity in coronary artery disease. Am J Cardiol. 1991;68(9):913-917. [pmid: 1927951]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Eriksson P, Gunnarsson G, Dellborg M. Diagnosis of acute myocardial infarction in patients with chronic left bundle-branch block. Standard 12-lead ECG compared to dynamic vectorcardiography. Scand Cardiovasc J. 1999;33(1):17-22. [pmid: 10093854]. Exclude - Does not include a relevant device
Eskola MJ, Nikus KC, Voipio-Pulkki LM, et al. Detection of proximal coronary occlusion in acute coronary syndrome: a feasibility study using computerized electrocardiographic analysis. Ann Noninvasive Electrocardiol. 2007;12(4):301-305. [pmid: 17970955]. Exclude - Does not include a relevant device
Exarchos TP, Papaloukas C, Fotiadis DI, et al. An association rule mining-based methodology for automated detection of ischemic ECG beats. IEEE Trans Biomed Eng. 2006;53(8):1531-1540. [pmid: 16916087]. Exclude - Does not include a relevant device
Farr BR, Vondenbusch B, Silny J, et al. Localization of significant coronary arterial narrowings using body surface potential mapping during exercise stress testing. Am J Cardiol. 1987;59(6):528-530. [pmid: 3548300]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Fenici R, Brisinda D, Meloni AM. Effects of filtering on computer-aided analysis for detection of chronic ischemic heart disease with unshielded rest magnetocardiographic mapping. Neurol Clin Neurophysiol. 2004;2004:7. [pmid: 16012666]. Exclude - Does not include a relevant device
Fenici R, Brisinda D, Meloni AM. Clinical application of magnetocardiography. Expert Rev Mol Diagn. 2005;5(3):291-313. [pmid: 15934809]. Exclude - Does not present original data
Fernandez EA, Willshaw P, Perazzo CA, et al. Detection of abnormality in the electrocardiogram without prior knowledge by using the quantisation error of a self-organising map, tested on the European ischaemia database. Med Biol Eng Comput. 2001;39(3):330-337. [pmid: 11465888]. Exclude - Does not include a relevant device
Ferro G, Spinelli L, Spadafora M, et al. Noninvasive approach to evaluate coronary reserve. Acta Cardiol. 1990;45(3):211-216. [pmid: 2368541]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Fetsch T, Pieterson AH, Borggrefe M, et al. Clinical indications for signal-averaged electrocardiographic analysis. Coron Artery Dis. 1991;2(1):33-41. Exclude - Does not present original data
Finlay DD, Nugent CD, Kors JA, et al. Optimizing the 12-lead electrocardiogram: a data driven approach to locating alternative recording sites. J Electrocardiol. 2007;40(3):292-299. [pmid: 17292383]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Finlay DD, Nugent CD, McCullagh PJ, et al. Mining for diagnostic information in body surface potential maps: a comparison of feature selection techniques. Biomed Eng Online. 2005;4:51. [pmid: 16138921]. Exclude - Does not include a relevant device
Fiol M, Carrillo A, Cygankiewicz I, et al. A new electrocardiographic algorithm to locate the occlusion in left anterior descending coronary artery. Clin Cardiol. 2009;32(11):E1-E6. [pmid: 19816974]. Exclude - Does not include a relevant device
Fox K, Selwyn A, Shillingford J. Precordial electrocardiographic mapping after exercise in the diagnosis of coronary artery disease. Am J Cardiol. 1979;43(3):541-546. [pmid: 420103]. Exclude - Does not include a relevant device
Fox TR, Burton JH, Strout TD, et al. Time to body surface map acquisition compared with ED 12-lead and right-sided ECG. Am J Emerg Med. 2003;21(2):164-165. [pmid: 12671826]. Exclude - Does not report relevant outcome (defined in inclusion criteria)
Gapelyuk A, Wessel N, Fischer R, et al. Detection of patients with coronary artery disease using cardiac magnetic field mapping at rest. J Electrocardiol. 2007;40(5):401-407. [pmid: 17531250]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Gauss A, Rohm HJ, Strahle A, et al. Noninvasive diagnosis of coronary artery disease: a comparison between cardiokymographic and electrocardiographic stress testing. Cardiology. 2001;96(2):100-105. [pmid: 11740139]. Exclude - Does not include a relevant device
Genma Y, Ogawa S, Zhang J, et al. Evaluation of myocardial ischemia in Kawasaki disease by dobutamine stress signal-averaged ventricular late potentials. Cardiovasc Res. 1997;36(3):323-329. [pmid: 9534852]. Exclude - Does not include a relevant device
Ghaffari A, Atarod M, Ghasemi M. Characterization of the location and extent of myocardial infarction using heart vector analysis. Cardiovasc Eng. 2009;9(1):6-10. [pmid: 19263222]. Exclude - Does not include a relevant device
Goernig M, Liehr M, Tute C, et al. Magnetocardiography based spatiotemporal correlation analysis is superior to conventional ECG analysis for identifying myocardial injury. Ann Biomed Eng. 2009;37(1):107-111. [pmid: 19015988]. Exclude - Does not include a relevant device
Golyshev NV, Motorin SV, Rogachevskii BM, et al. Magnetocardiographic examination in clinical diagnosis of cardiac pathology. Biomed Eng. 1995;29(4):167-170. Exclude - Does not include a relevant device
Gomis P, Jones DL, Caminal P, et al. Analysis of abnormal signals within the QRS complex of the high-resolution electrocardiogram. IEEE Trans Biomed Eng. 1997;44(8):681-693. [pmid: 9254982]. Exclude - Does not include a relevant device
Gould LA, Betzu R, Judge D, et al. The resting cardiointegram: correlation with stress thallium perfusion studies. Angiology. 1988;39(4):375-380. [pmid: 3364804]. Exclude - Does not include a relevant device
Graham AA, Handelsman H. Signal-averaged electrocardiography. Health Technol Assess (Rockv). 1998;(11):i-vi. 1. 15. [pmid: 9803322]. Exclude - Does not present original data
Gramatikov B, Yi-Chun S, Rix H, et al. Multiresolution wavelet analysis of the body surface ECG before and after angioplasty. Ann Biomed Eng. 1995;23(5):553-561. [pmid: 7503458]. Exclude - Does not include a relevant device
Green LS, Abildskov JA. Clinical applications of body surface potential mapping. Clin Cardiol. 1995;18(5):245-249. [pmid: 7628129]. Exclude - Does not present original data
Green LS, Lux RL, Haws CW. Detection and localization of coronary artery disease with body surface mapping in patients with normal electrocardiograms. Circulation. 1987;76(6):1290-1297. [pmid: 3677354]. Exclude - Does not include a relevant device
Greenberg R, Morganroth J, Zelenkofske S, et al. Signal-averaged electrocardiography and ambulatory monitoring. Cardiovasc Clin. 1992;22(1):47-69. [pmid: 1728436]. Exclude - Does not present original data
Grube E, Bootsveld A, Buellesfekd L, et al. Computerized two-lead resting ECG analysis for the detection of coronary artery stenosis after coronary revascularization. Int J Med Sci. 2008;5(2):50-61. [pmid: 18345283]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Grube E, Bootsveld A, Yuecel S, et al. Computerized two-lead resting ECG analysis for the detection of coronary artery stenosis. Int J Med Sci. 2007;4(5):249-263. [pmid: 18026565]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Hailer B, Chaikovsky I, Auth-Eisernitz S, et al. Magnetocardiography in coronary artery disease with a new system in an unshielded setting. Clin Cardiol. 2003;26(10):465-471. [pmid: 14579917]. Exclude - Does not include a relevant device
Hailer B, Chaikovsky I, Auth-Eisernitz S, et al. The value of magnetocardiography in patients with and without relevant stenoses of the coronary arteries using an unshielded system. Pacing Clin Electrophysiol. 2005;28(1):8-16. [pmid: 15660796]. Exclude - Does not include a relevant device
Hailer B, Van Leeuwen P. Detection of coronary artery disease with MCG. Neurol Clin Neurophysiol. 2004;2004:82. [pmid: 16012675]. Exclude - Does not present original data
Hailer B, Van Leeuwen P, Chaikovsky I, et al. The value of magnetocardiography in the course of coronary intervention. Ann Noninvasive Electrocardiol. 2005;10(2):188-196. [pmid: 15842431]. Exclude - Does not include a relevant device
Hailer B, Van Leeuwen P, Lange S, et al. Coronary artery disease may alter the spatial dispersion of the QT interval at rest. Ann Noninvasive Electrocardiol. 1999;4(3):267-273. Exclude - Does not include a relevant device
Hailer B, Van Leeuwen P, Lange S, et al. Spatial distribution of QT dispersion measured by magnetocardiography under stress in coronary artery disease. J Electrocardiol. 1999;32(3):207-216. [pmid: 10465564]. Exclude - Does not include a relevant device
Hanninen H, Takala P, Korhonen P, et al. Features of ST segment and T-wave in exercise-induced myocardial ischemia evaluated with multichannel magnetocardiography. Ann Med. 2002;34(2):120-129. [pmid: 12108575]. Exclude - Does not include a relevant device
Hanninen H, Takala P, Makijarvi M, et al. ST-segment level and slope in exercise-induced myocardial ischemia evaluated with body surface potential mapping. Am J Cardiol. 2001;88(10):1152-1156. [pmid: 11703962]. Exclude - Does not present original data
Hanninen H, Takala P, Makijarvi M, et al. Detection of exercise-induced myocardial ischemia by multichannel magnetocardiography in single vessel coronary artery disease. Ann Noninvasive Electrocardiol. 2000;5(2):147-157. Exclude - Does not include a relevant device
Hanninen H, Takala P, Makijarvi M, et al. Recording locations in multichannel magnetocardiography and body surface potential mapping sensitive for regional exercise-induced myocardial ischemia. Basic Res Cardiol. 2001;96(4):405-414. [pmid: 11518197]. Exclude - Does not include a relevant device
Hanninen H, Takala P, Rantonen J, et al. ST-T integral and T-wave amplitude in detection of exercise-induced myocardial ischemia evaluated with body surface potential mapping. J Electrocardiol. 2003;36(2):89-98. [pmid: 12764690]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Hatrick R, Teece S, Curzen N. Seeing transient regional myocardial ischaemia through new eyes. Int J Cardiovasc Intervent. 2005;7(3):155-158. [pmid: 16243739]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Hayashi H, Watanabe Y, Ishikawa T, et al. Diagnostic value of body surface map in myocardial infarction: assessment of location, size and ejection fraction as compared with coronary cineangiography and 201Tl myocardial scintigraphy. Jpn Circ J. 1980;44(3):197-208. [pmid: 7365992]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Hollander JE. The 80-lead ECG: more expensive NSTEMI or Occult STEMI. Ann Emerg Med. 2009;54(6):789-790. [pmid: 19766356]. Exclude - Does not present original data
Hombach V, Braun V, Hopp HW, et al. The applicability of the signal averaging technique in clinical cardiology. Clin Cardiol. 1982;5(2):107-124. [pmid: 7039898]. Exclude - Does not include a relevant device
Hombach V, Clausen M, Osterhues HH, et al. Methodological aspects of detecting patients with symptomatic and silent myocardial ischemia. Adv Cardiol. 1990;37:76-95. [pmid: 2220468]. Exclude - Does not include a relevant device
Hombach V, Hopp HW, Kebbel U, et al. Recovery of ventricular late potentials from body surface using the signal averaging and high resolution ECG techniques. Clin Cardiol. 1986;9(8):361-368. [pmid: 3731561]. Exclude - Does not include a relevant device
Horacek BM, Wagner GS. Electrocardiographic ST-segment changes during acute myocardial ischemia. Card Electrophysiol Rev. 2002;6(3):196-203. [pmid: 12114838]. Exclude - Does not present original data
Horacek BM, Warren JW, Penney CJ, et al. Optimal electrocardiographic leads for detecting acute myocardial ischemia. J Electrocardiol. Suppl. 2001;34:97-111. [pmid: 11781943]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Horwitz LI. Current clinical utility of body surface mapping. J Invasive Cardiol. 1995;7(9):265-274. [pmid: 10158379]. Exclude - Does not present original data
Hosokawa J, Shen JT, Imhoff M. Computerized 2-lead resting ECG analysis for the detection of relevant coronary artery stenosis in comparison with angiographic findings. Congest Heart Fail. 2008;14(5):251-260. [pmid: 18983288]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Huebner T, Goernig M, Schuepbach M, et al. Electrocardiologic and related methods of non-invasive detection and risk stratification in myocardial ischemia: state of the art and perspectives. Ger Med Sci. 2010;8:Doc27. [pmid: 21063467]. Exclude - Does not present original data
Huebner T, Schuepbach WM, Seeck A, et al. Cardiogoniometric parameters for detection of coronary artery disease at rest as a function of stenosis localization and distribution. Med Biol Eng Comput. 2010;48(5):435-446. [pmid: 20300872]. Exclude - Does not include a relevant device
Hulin I, Slavkovsky P, Hatala R, et al. Gliding window fast Fourier transform analysis--a new method for discovering the contribution of higher frequencies in signal-averaged ECG. Can J Cardiol. 1993;9(9):789-796. [pmid: 8281478]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Igosheva N, Gridnev V, Kotelnikova E, et al. Effects of external periodic perturbations on short-term heart rate variability in healthy subjects and ischemic heart disease patients. Int J Cardiol. 2003;90(1):91-106. [pmid: 12821224]. Exclude - Does not include a relevant device
Ikeda K, Kawashima S, Kubota I, et al. Non-invasive detection of coronary artery disease by body surface electrocardiographic mapping after dipyridamole infusion. J Electrocardiol. 1986;19(3):213-223. [pmid: 3746148]. Exclude - Does not include a relevant device
Ikeda K, Kubota I, Tonooka I, et al. Detection of posterior myocardial infarction by body surface mapping: a comparative study with 12 lead ECG and VCG. J Electrocardiol. 1985;18(4):361-369. [pmid: 4067469]. Exclude - Does not include a relevant device
Ikeda K, Kubota I, Yamaki M, et al. Dipyridamole electrocardiography test for the detection of severe coronary artery stenoses. Intern Med. 1992;31(2):147-153. [pmid: 1600258]. Exclude - Does not include a relevant device
Jager F. Guidelines for assessing performance of ST analysers. J Med Eng Technol. 1998;22(1):25-30. [pmid: 9491355]. Exclude - Does not include a relevant device
Janosi A, Istvanffy M, Kozmann G, et al. Diagnosis of ischemic heart disease by multiple techniques: Correlation with coronary arteriograms. J Cardpulm Rehabil. 1987;7(3):145-149. Exclude - Does not include a relevant device
Jayachandran ES, Joseph KP, Acharya UR. Analysis of myocardial infarction using discrete wavelet transform. J Med Syst. 2010;34(6):985-992. [pmid: 20703609]. Exclude - Does not include a relevant device
Kampouraki A, Manis G, Nikou C. Heartbeat time series classification with support vector machines. IEEE Trans Inf Technol Biomed. 2009;13(4):512-518. [pmid: 19273030]. Exclude - Does not include a relevant device
Kanzaki H, Nakatani S, Kandori A, et al. A new screening method to diagnose coronary artery disease using multichannel magnetocardiogram and simple exercise. Basic Res Cardiol. 2003;98(2):124-132. [pmid: 12607134]. Exclude - Does not include a relevant device
Karadede A, Aydinalp O, Temamogullari AV, et al. The relationship of ST segment elevation shape with preserved myocardium and signal-averaged electrocardiography in acute anterior myocardial infarction. Heart Vessels. 2002;16(4):146-153. [pmid: 12224785]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Kilpatrick D, Bell AJ. The relationship of ST elevation to eventual QRS loss in acute inferior myocardial infarction. J Electrocardiol. 1989;22(4):343-348. [pmid: 2794836]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Kornreich F. Body surface mapping: a practical cardiac imaging tool?. Acta Cardiol. 1988;43(6):639-652. [pmid: 3266412]. Exclude - Does not present original data
Kornreich F. Identification of best electrocardiographic leads for diagnosing acute myocardial ischemia. J Electrocardiol. Suppl. 1998;31:157-163. [pmid: 9988022]. Exclude - Does not include a relevant device
Kornreich F, Lux RL, MacLeod RS. Map representation and diagnostic performance of the standard 12-lead ECG. J Electrocardiol. Suppl. 1995;28:121-123. [pmid: 8656098]. Exclude - Does not include a relevant device
Kornreich F, MacLeod RS, Lux RL. Supplemented standard 12-lead electrocardiogram for optimal diagnosis and reconstruction of significant body surface map patterns. J Electrocardiol. 2008;41(3):251-256. [pmid: 18433616]. Exclude - Does not include a relevant device
Kornreich F, Montague TJ, Rautaharju PM. Body surface potential mapping of ST segment changes in acute myocardial infarction. Implications for ECG enrollment criteria for thrombolytic therapy. Circulation. 1993;87(3):773-782. [pmid: 8443898]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Kors JA, van Herpen G. Mirror image electrocardiograms and additional electrocardiographic leads: new wine in old wineskins?. J Electrocardiol. 2008;41(3):245-250. [pmid: 18367201]. Exclude - Does not include a relevant device
Kubota I, Hanashima K, Ikeda K, et al. Detection of diseased coronary artery by exercise ST-T maps in patients with effort angina pectoris, single-vessel disease, and normal ST-T wave on electrocardiogram at rest. Circulation. 1989;80(1):120-127. [pmid: 2736744]. Exclude - Does not include a relevant device
Kubota I, Watanabe Y, Harada M, et al. Treadmill stress test using body surface mapping in coronary artery disease--the clinical significance of ST depression. Jpn Circ J. 1982;46(1):8-15. [pmid: 7054579]. Exclude - Does not include a relevant device
Kwon H, Kim K, Lee YH, et al. Non-invasive magnetocardiography for the early diagnosis of coronary artery disease in patients presenting with acute chest pain. Circ J. 2010;74(7):1424-1430. [pmid: 20508380]. Exclude - Does not include a relevant device
Kylmala MM, Konttila T, Vesterinen P, et al. Body surface potential mapping predicts recovery of acute ischemic left ventricular dysfunction. Eur Heart J. 2011;32:737. [pmid: 21266374]. Exclude - Not a full peer-reviewed publication
Kyoon Lim H, Kim K, Lee YH, et al. Detection of non-ST-elevation myocardial infarction using magnetocardiogram: new information from spatiotemporal electrical activation map. Ann Med. 2009;41(7):533-546. [pmid: 19626486]. Exclude - Does not include a relevant device
Lander P, Gomis P, Gates K, et al. Comparison of high-resolution and standard ECG parameters of myocardial ischemia during PTCA. J Electrocardiol. Suppl. 1996;29:167. [pmid: 9238395]. Exclude - Not a full peer-reviewed publication
Lander P, Gomis P, Warren S, et al. Abnormal intra-QRS potentials associated with percutaneous transluminal coronary angiography-induced transient myocardial ischemia. J Electrocardiol. 2006;39(3):282-289. [pmid: 16777514]. Exclude - Sample size < 20 patients
Lefebvre C, Hoekstra J. Early detection and diagnosis of acute myocardial infarction: the potential for improved care with next-generation, user-friendly electrocardiographic body surface mapping. Am J Emerg Med. 2007;25(9):1063-1072. [pmid: 18022503]. Exclude - Does not present original data
Leonarduzzi RF, Schlotthauer G, Torres ME. Wavelet leader based multifractal analysis of heart rate variability during myocardial ischaemia. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:110-113. [pmid: 21095648]. Exclude - Does not include a relevant device
Li G, He B. Non-invasive estimation of myocardial infarction by means of a heart-model-based imaging approach: a simulation study. Med Biol Eng Comput. 2004;42(1):128-136. [pmid: 14977234]. Exclude - Does not include a relevant device
Lim HK, Chung N, Kim K, et al. Can magnetocardiography detect patients with non-ST-segment elevation myocardial infarction?. Ann Med. 2007;39(8):617-627. [pmid: 17852033]. Exclude - Does not include a relevant device
Lim HK, Kwon H, Chung N, et al. Usefulness of magnetocardiogram to detect unstable angina pectoris and non-ST elevation myocardial infarction. Am J Cardiol. 2009;103(4):448-454. [pmid: 19195500]. Exclude - Does not include a relevant device
Lipton JA, Warren SG, Broce M, et al. High-frequency QRS electrocardiogram analysis during exercise stress testing for detecting ischemia. Int J Cardiol. 2008;124(2):198-203. [pmid: 17462756]. Exclude - Does not include a relevant device
Lux RL, MacLeod RS, Fuller M, et al. Estimating ECG distributions from small numbers of leads. J Electrocardiol. Suppl. 1995;28:92-98. [pmid: 8656136]. Exclude - Does not include a relevant device
MacLeod RS, Brooks DH, On H, et al. Analysis of PTCA-induced ischemia using an ECG inverse solution or the wavelet transform. J Electrocardiol. Suppl. 1994;27:93-100. [pmid: 7884383]. Exclude - Does not include a relevant device
MacLeod RS, Gardner M, Miller RM, et al. Application of an electrocardiographic inverse solution to localize ischemia during coronary angioplasty. J Cardiovasc Electrophysiol. 1995;6(1):2-18. [pmid: 7743006]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Madias JE. Body surface maps and standard electrocardiograms in patients with acute myocardial infarctions: a paucity of data from the posterior thorax?. Am J Cardiol. 2008;102(8):1117. [pmid: 18929726]. Exclude - Does not present original data
Matsumoto M, Hiraki T, Yoshida T, et al. Portable type signal-averaged electrocardiography with dipyridamole: a new and convenient method to detect patients with coronary artery disease and ischemia. Circ J. 2005;69(6):659-665. [pmid: 15914942]. Exclude - Does not include a relevant device
Matveev M, Krasteva V, Naydenov S, et al. Possibilities of signal-averaged orthogonal and vector electrocardiography for locating and size evaluation of acute myocardial infarction with ST-elevation. Anadolu Kardiyol Derg. Suppl 1. 2007;7:193-197. [pmid: 17584723]. Exclude - Does not include a relevant device
Maynard SJ, Riddell JW, Menown IB, et al. Body surface potential mapping improves detection of ST segment alteration during percutaneous coronary intervention. Int J Cardiol. 2004;93(2–3):203-210. [pmid: 14975548]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
McMechan SR, Cullen CM, MacKenzie G, et al. Discriminant function analysis of body surface potential maps in acute myocardial infarction. J Electrocardiol. Suppl. 1994;27:117-120. [pmid: 7884345]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
McMechan SR, MacKenzie G, Allen J, et al. Body surface ECG potential maps in acute myocardial infarction. J Electrocardiol. Suppl. 1995;28:184-190. [pmid: 8656109]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Medvegy M, Duray G, Pinter A, et al. Body surface potential mapping: historical background, present possibilities, diagnostic challenges. Ann Noninvasive Electrocardiol. 2002;7(2):139-151. [pmid: 12049686]. Exclude - Does not present original data
Medvegy M, Preda I, Savard P, et al. New body surface isopotential map evaluation method to detect minor potential losses in non-Q-wave myocardial infarction. Circulation. 2000;101(10):1115-1121. [pmid: 10715257]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Medvegy M, Savard P, Pinter A, et al. Simple, quantitative body surface potential map parameters in the diagnosis of remote Q wave and non-Q wave myocardial infarction. Can J Cardiol. 2004;20(11):1109-1115. [pmid: 15457307]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Meier A, Hoflin F, Herrmann HJ, et al. Comparative diagnostic value of a new computerized vectorcardiographic method (cardiogoniometry) and other noninvasive tests in medically treated patients with chest pain. Clin Cardiol. 1987;10(5):311-316. [pmid: 3594943]. Exclude - Does not include a relevant device
Menown IB, Allen J, Anderson JM, et al. Early diagnosis of right ventricular or posterior infarction associated with inferior wall left ventricular acute myocardial infarction. Am J Cardiol. 2000;85(8):934-938. [pmid: 10760329]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Menown IBA. Body surface mapping improves early identification of acute myocardial infarction in patients with ST depression only on the initial 12-lead ECG. Cardiovascular Reviews and Reports. 2002;23(5):262-268. Exclude - Does not present original data
Menown IBA. Body Surface Mapping: Potential Role in a Chest Pain Critical Care Pathway. Crit Pathw Cardiol. 2003;2(1):46-51. [pmid: 18340318]. Exclude - Does not present original data
Montague TJ, Smith ER, Johnstone DE, et al. Temporal evolution of body surface map patterns following acute inferior myocardial infarction. J Electrocardiol. 1984;17(4):319-327. [pmid: 6502049]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Montague TJ, Witkowski FX. The clinical utility of body surface potential mapping in coronary artery disease. Am J Cardiol. 1989;64(5):378-383. [pmid: 2526994]. Exclude - Does not present original data
Montague TJ, Witkowski FX, Miller RM, et al. Exercise body surface potential mapping in single and multiple coronary artery disease. Chest. 1990;97(6):1333-1342. [pmid: 2347218]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Morguet AJ, Behrens S, Kosch O, et al. Myocardial viability evaluation using magnetocardiography in patients with coronary artery disease. Coron Artery Dis. 2004;15(3):155-162. [pmid: 15096996]. Exclude - Does not include a relevant device
Morise AP, Beto R, Gupta N, et al. Exercise QT dispersion as an independent predictor of the presence of ischemia on myocardial perfusion imaging. Ann Noninvasive Electrocardiol. 2000;5(3):240-247. Exclude - Does not include a relevant device
Murray C, Alpert JS. Diagnosis of acute myocardial infarction. Curr Opin Cardiol. 1994;9(4):465-470. [pmid: 7919591]. Exclude - Does not present original data
Myrianthefs MM, Ellestad MH, Startt-Selvester RH, et al. Significance of signal-averaged P-wave changes during exercise in patients with coronary artery disease and correlation with angiographic findings. Am J Cardiol. 1991;68(17):1619-1624. [pmid: 1746463]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Nakai K, Izumoto H, Kawazoe K, et al. Three-dimensional recovery time dispersion map by 64-channel magnetocardiography may demonstrate the location of a myocardial injury and heterogeneity of repolarization. Int J Cardiovasc Imaging. 2006;22(3–4):573-580. [pmid: 16307313]. Exclude - Does not include a relevant device
Nakajima T, Kawakubo K, Toda I, et al. ST-T isointegral analysis of exercise stress body surface mapping for identifying ischemic areas in patients with angina pectoris. Am Heart J. 1988;115(5):1013-1021. [pmid: 3364334]. Exclude - Does not include a relevant device
Neill J, Owens C, Harbinson M, et al. Early detection of acute posterior myocardial infarction using body surface mapping and SPECT scanning. Coron Artery Dis. 2010;21(7):420-427. [pmid: 20700053]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Nenonen J, Pesola K, Hanninen H, et al. Current-density estimation of exercise-induced ischemia in patients with multivessel coronary artery disease. J Electrocardiol. Suppl. 2001;34:37-42. [pmid: 11781934]. Exclude - Does not include a relevant device
Nishiyama A, Suzuki A, Hayashi H, et al. Comparative study of QRST values from body surface potential mapping, 12-lead ECGs, VCGs in detecting inferior myocardial infarction, and evaluating the severity of left ventricular wall motion abnormalities in simulated left bundle branch block. J Electrocardiol. 1993;26(3):187-196. [pmid: 8409813]. Exclude - Does not include a relevant device
Ohyu S, Okamoto Y, Kuriki S. Use of the ventricular propagated excitation model in the magnetocardiographic inverse problem for reconstruction of electrophysiological properties. IEEE Trans Biomed Eng. 2002;49(6):509-519. [pmid: 12046695]. Exclude - Does not include a relevant device
On K, Watanabe S, Yamada S, et al. Integral value of JT interval in magnetocardiography is sensitive to coronary stenosis and improves soon after coronary revascularization. Circ J. 2007;71(10):1586-1592. [pmid: 17895556]. Exclude - Does not include a relevant device
O’Rourke RA, McCall D. Current usefulness of the signal-averaged electrocardiogram. Curr Probl Cardiol. 1993;18(6):365-418. Exclude - Not a full peer-reviewed publication
Paquay JL, Zimmermann M, Mermillod B, et al. Immediate and day-to-day reproducibility of the signal-averaged electrocardiogram in patients with coronary artery disease. Pacing Clin Electrophysiol. 1996;19(4 Pt 1):443-454. [pmid: 8848392]. Exclude - Does not include a relevant device
Park JW, Hill PM, Chung N, et al. Magnetocardiography predicts coronary artery disease in patients with acute chest pain. Ann Noninvasive Electrocardiol. 2005;10(3):312-323. [pmid: 16029382]. Exclude - Does not include a relevant device
Park JW, Jung F. Qualitative and quantitative description of myocardial ischemia by means of magnetocardiography. Biomed Tech (Berl). 2004;49(10):267-273. [pmid: 15566075]. Exclude - Does not include a relevant device
Park JW, Leithauser B, Hill P, et al. Resting magnetocardiography predicts 3-year mortality in patients presenting with acute chest pain without ST segment elevation. Ann Noninvasive Electrocardiol. 2008;13(2):171-179. [pmid: 18426443]. Exclude - Does not include a relevant device
Park JW, Leithauser B, Jung F. Magnetocardiography predicts coronary artery disease in bundle-branch block patients with acute chest pain. J Electrocardiol. 2007;40(1 SUPPL):S53. Exclude - Does not include a relevant device
Park JW, Leithauser B, Vrsansky M, et al. Dobutamine stress magnetocardiography for the detection of significant coronary artery stenoses - a prospective study in comparison with simultaneous 12-lead electrocardiography. Clin Hemorheol Microcirc. 2008;39(1–4):21-32. [pmid: 18503107]. Exclude - Does not include a relevant device
Parthenakis FI, Manios EM, Tsagarakis CG, et al. Effects of a positive exercise test on the signal-averaged electrocardiogram in non-syncopal ischaemic patients. Hellenic J Cardiol. 1993;34(3):276-281. Exclude - Article not published in English
Perez-Alard J, Desai PR, Sirithara R, et al. Correlation of Holter monitoring and left ventricular function to signal-averaged electrocardiogram after myocardial infarction. Md Med J. 1991;40(5):375-378. [pmid: 2041462]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Pettersson J, Carro E, Edenbrandt L, et al. Spatial, individual, and temporal variation of the high-frequency QRS amplitudes in the 12 standard electrocardiographic leads. Am Heart J. 2000;139(2 Pt 1):352-358. [pmid: 10650310]. Exclude - Does not include a relevant device
Pettersson J, Edenbrandt L, Pahlm O, et al. Enhancement of diagnostic performance of the 12-lead ECG by using measurements from the synthesized vectorcardiogram. J Electrocardiol. Suppl. 1993;26:95. [pmid: 8189155]. Exclude - Does not include a relevant device
Pettersson J, Lander P, Pahlm O, et al. Electrocardiographic changes during prolonged coronary artery occlusion in man: comparison of standard and high-frequency recordings. Clin Physiol. 1998;18(3):179-186. [pmid: 9649905]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Pettersson J, Pahlm O, Carro E, et al. Changes in high-frequency QRS components are more sensitive than ST-segment deviation for detecting acute coronary artery occlusion. J Am Coll Cardiol. 2000;36(6):1827-1834. [pmid: 11092652]. Exclude - Does not include a relevant device
Provaznik I, Kozumplik J, Bardonova J, et al. Time-frequency analysis of electrocardiograms. Lekar a Technika. 2003;34(2):60-67. Exclude - Does not include a relevant device
Pruvost P, Lablanche JM, Beuscart R, et al. Enhanced efficacy of computerized exercise test by multivariate analysis for the diagnosis of coronary artery disease. A study of 558 men without previous myocardial infarction. Eur Heart J. 1987;8(12):1287-1294. [pmid: 3325288]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Pueyo E, Sornmo L, Laguna P. QRS slopes for detection and characterization of myocardial ischemia. IEEE Trans Biomed Eng. 2008;55(2 Pt 1):468-477. [pmid: 18269981]. Exclude - Does not include a relevant device
Ragosta M, Pagley PR, DiMarco JP, et al. Relation between myocardial viability and abnormalities on the signal-averaged electrocardiogram in patients with low (<40%) ejection fraction and coronary artery disease. Am J Cardiol. 2000;85(4):405-410. [pmid: 10728941]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Rahman AM, Gedevanishvili A, Bungo MW, et al. Non-invasive detection of coronary artery disease by a newly developed high-frequency QRS electrocardiogram. Physiol Meas. 2004;25(4):957-965. [pmid: 15382834]. Exclude - Sample size < 20 patients
Reddy BR, Christenson DW, Rowlandson GI. High-resolution ECG on a standard ECG cart. J Electrocardiol. Suppl. 1988;21:S74-S79. [pmid: 3216180]. Exclude - Does not include a relevant device
Ringborn M, Pettersson J, Persson E, et al. Comparison of high-frequency QRS components and ST-segment elevation to detect and quantify acute myocardial ischemia. J Electrocardiol. 2010;43(2):113-120. [pmid: 20060122]. Exclude - Does not include a relevant device
Robinson M, Bannister C, Reddiar R, et al. Cardiovascular images. Detecting transient myocardial ischemia in the context of acute coronary syndrome in the emergency department: Delta map analysis of body electrocardiographic surface mapping. Circ Cardiovasc Imaging. 2009;2(3):e17-e19. [pmid: 19808584]. Exclude - Does not present original data
Robinson MR, Curzen N. Electrocardiographic body surface mapping: potential tool for the detection of transient myocardial ischemia in the 21st century?. Ann Noninvasive Electrocardiol. 2009;14(2):201-210. [pmid: 19419406]. Exclude - Does not present original data
Rodriguez JD, De Los Santos L. Comparative analysis using the 80-lead body surface map and 12-lead ECG with exercise stress echocardiograms. Journal of Diagnostic Medical Sonography. 2006;22(5):308-316. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Romero D, Ringborn M, Laguna P, et al. Depolarization changes during acute myocardial ischemia by evaluation of QRS slopes: standard lead and vectorial approach. IEEE Trans Biomed Eng. 2011;58(1):110-120. [pmid: 20840890]. Exclude - Does not include a relevant device
Rooks J. Current technologies for detection of myocardial ischemia during acute care. Intensive Care World. 1991;8(1):22-24. [pmid: 10148910]. Exclude - Does not present original data
Rozenman Y, Rotzak R, Patterson RP. Detection of left ventricular systolic dysfunction using a newly developed, laptop based, impedance cardiographic index. Int J Cardiol. 2011;149(2):248-249. [pmid: 21396726]. Exclude - Does not include a relevant device
Russell DC. Continuous body surface potential mapping during the early hours of acute myocardial infarction. J Electrocardiol. Suppl. 1990;23:207. [pmid: 2090748]. Exclude - Not a full peer-reviewed publication
Saetre HA, Selvester RH, Solomon JC, et al. 16-lead ECG changes with coronary angioplasty. Location of ST-T changes with balloon occlusion of five arterial perfusion beds. J Electrocardiol. Suppl. 1992;24:153-162. [pmid: 1552250]. Exclude - Does not include a relevant device
Saner H, Baur HR, Sanz E, et al. Cardiogoniometry: a new noninvasive method for detection of ischemic heart disease. Clin Cardiol. 1983;6(5):207-210. [pmid: 6851279]. Exclude - Does not include a relevant device
Sanz E, Steger JP, Thie W. Cardiogoniometry. Clin Cardiol. 1983;6(5):199-206. [pmid: 6851278]. Exclude - Does not include a relevant device
Sasaki A, Arai T, Shigeta H, et al. Detection of silent myocardial ischemia patients by the spatial velocity electrocardiogram. Am J Cardiol. 1999;84(9):1081-1083. A9. [pmid: 10569668]. Exclude - Does not include a relevant device
Sasaki R, Sugisawa K, Iwasaki T. Use of the body surface recovery time for detection of coronary artery disease. Jpn Heart J. 1997;38(3):345-360. [pmid: 9290569]. Exclude - Does not include a relevant device
Scherhag AW, Pfleger S, Ceconi C, et al. Evaluation of signal-averaged cardiokymography for the detection of ischaemic left ventricular dysfunction. Int J Cardiol. 1997;59(3):305-312. [pmid: 9183048]. Exclude - Does not include a relevant device
Schlegel TT, Kulecz WB, DePalma JL, et al. Real-time 12-lead high-frequency QRS electrocardiography for enhanced detection of myocardial ischemia and coronary artery disease. Mayo Clin Proc. 2004;79(3):339-350. [pmid: 15008608]. Exclude - Does not present original data
Schreck DM, Ng L, Schreck BS, et al. Detection of coronary artery disease from the normal resting ECG using nonlinear mathematical transformation. Ann Emerg Med. 1988;17(2):132-134. [pmid: 3276247]. Exclude - Does not include a relevant device
Schupbach WM, Emese B, Loretan P, et al. Non-invasive diagnosis of coronary artery disease using cardiogoniometry performed at rest. Swiss Med Wkly. 2008;138(15–16):230-238. [pmid: 18431698]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Scott PJ, Navarro C, Stevenson M, et al. Optimization of the precordial leads of the 12-lead electrocardiogram may improve detection of ST-segment elevation myocardial infarction. J Electrocardiol. 2011;44(4):425-431. [pmid: 21704220]. Exclude - Study does not address target population, or does not address diagnosing CAD, ischemia, or ACS
Self WH, Mattu A, Martin M, et al. Body surface mapping in the ED evaluation of the patient with chest pain: use of the 80-lead electrocardiogram system. Am J Emerg Med. 2006;24(1):87-112. [pmid: 16338516]. Exclude - Does not present original data
Selker HP, Zalenski RJ, Antman EM, et al. An evaluation of technologies for identifying acute cardiac ischemia in the emergency department: a report from a National Heart Attack Alert Program Working Group. Ann Emerg Med. 1997;29(1):13-87. [pmid: 8998086]. Exclude - Does not present original data
Selker HP, Zalenski RJ, Antman EM, et al. An evaluation of technologies for identifying acute cardiac ischemia in the emergency department: executive summary of a National Heart Attack Alert Program Working Group Report. Ann Emerg Med. 1997;29(1):1-12. [pmid: 8998085]. Exclude - Does not present original data
Selvester RH. The signal-averaged high-resolution ECG. J Electrocardiol. Suppl. 1995;28:216-225. [pmid: 8656117]. Exclude - Does not present original data
Sobieszczanska M, Kalka D, Pilecki W, et al. Application of body surface potential mapping in coronary artery disease diagnosis. Anadolu Kardiyol Derg. Suppl 1. 2007;7:16-19. [pmid: 17584671]. Exclude - Does not include a relevant device
Solomon AJ, Tracy CM. The Signal-averaged electrocardiogram in predicting coronary artery disease. Am Heart J. 1991;122(5):1334-1339. [pmid: 1950997]. Exclude - Does not include a relevant device
Sridharan MR, Horan LG, Hand RC, et al. Use of body surface maps to identify vessel site of coronary occlusion. J Electrocardiol. Suppl. 1989;22:72-81. [pmid: 2614318]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Steinberg BA, Roguin A, Watkins SP 3rd. Magnetocardiogram recordings in a nonshielded environment--reproducibility and ischemia detection. Ann Noninvasive Electrocardiol. 2005;10(2):152-160. [pmid: 15842427]. Exclude - Does not include a relevant device
Stilli D, Musso E, Macchi E, et al. Body surface potential mapping in ischemic patients with normal resting ECG. Can J Cardiol. Suppl A. 1986:107A-112A. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Strobeck JE, Shen JT, Singh B, et al. Comparison of a two-lead, computerized, resting ECG signal analysis device, the MultiFunction-CardioGram or MCG (a.k.a. 3DMP), to quantitative coronary angiography for the detection of relevant coronary artery stenosis (>70%) - a meta-analysis of all published trials performed and analyzed in the US. Int J Med Sci. 2009;6(4):143-155. [pmid: 19381351]. Exclude - Does not present original data
Szucs E, Szakolczai K, Simonyi G, et al. Diagnostic value of body surface potential mapping in assessment of the coronary artery lesion after angina pectoris and without repolarization changes on the electrocardiogram. J Electrocardiol. 2010;43(4):326-335. [pmid: 20381065]. Exclude - Does not include a relevant device
Takaki H, Tahara N, Miyazaki S, et al. Exercise-induced QRS prolongation in patients with mild coronary artery disease: computer analysis of the digitized multilead ECGs. J Electrocardiol. Suppl. 1999;32:206-211. [pmid: 10688327]. Exclude - Does not include a relevant device
Takala P, Hanninen H, Montone J, et al. Magnetocardiographic and electrocardiographic exercise mapping in healthy subjects. Ann Biomed Eng. 2001;29(6):501-509. [pmid: 11459344]. Exclude - Does not include a relevant device
Takala P, Hanninen H, Montonen J, et al. Heart rate adjustment of magnetic field map rotation in detection of myocardial ischemia in exercise magnetocardiography. Basic Res Cardiol. 2002;97(1):88-96. [pmid: 11998980]. Exclude - Does not include a relevant device
Tavazzi L, Guagliumi G, Galli M, et al. Can body surface mapping improve the diagnostic power of standard electrocardiography in effort myocardial ischemia?. Can J Cardiol. Suppl A. 1986:99A-106A. Exclude - Does not include a relevant device
Terada Y. Did the global myocardial ischemia produce an influence on high-frequency QRS potentials?. Ann Thorac Surg. 2005;80(4):1563-1564. author reply 1564. [pmid: 16181924]. Exclude - Not a full peer-reviewed publication
Tilser P, Malkova A, Valova D, et al. Body surface potential mapping (BSPM) before and after percutaneous transluminal coronary angioplasty (PTCA). Physiol Res. 1993;42(2):131-134. [pmid: 8218133]. Exclude - Does not include a relevant device
Toledo E, Lipton JA, Warren SG, et al. Detection of stress-induced myocardial ischemia from the depolarization phase of the cardiac cycle--a preliminary study. J Electrocardiol. 2009;42(3):240-247. [pmid: 19249795]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Tolstrup K, Madsen BE, Ruiz JA, et al. Non-invasive resting magnetocardiographic imaging for the rapid detection of ischemia in subjects presenting with chest pain. Cardiology. 2006;106(4):270-276. [pmid: 16733351]. Exclude - Does not include a relevant device
Tragardh E. High-frequency electrocardiogram in acute myocardial ischemia. J Electrocardiol. 2006;39(1):87. [pmid: 16387058]. Exclude - Does not present original data
Tragardh E, Pahlm O, Wagner GS, et al. Reduced high-frequency QRS components in patients with ischemic heart disease compared to normal subjects. J Electrocardiol. 2004;37(3):157-162. [pmid: 15286928]. Exclude - Does not include a relevant device
Tragardh E, Schlegel TT. High-frequency QRS electrocardiogram. Clin Physiol Funct Imaging. 2007;27(4):197-204. [pmid: 17564667]. Exclude - Does not present original data
Tseng YZ, Hsu KL, Chiang FT, et al. Characteristic findings of body surface potential map during ventricular repolarization in patients with coronary heart disease. Jpn Heart J. 1999;40(4):391-404. [pmid: 10611904]. Exclude - Does not include a relevant device
Tseng YZ, Hsu KL, Chiang FT, et al. Implications of an early reversal pattern of body surface potential maps in coronary artery disease. J Formos Med Assoc. 1999;98(5):309-313. [pmid: 10420697]. Exclude - Does not report a relevant outcome (defined in inclusion criteria)
Tsukada K, Miyashita T, Kandori A, et al. An iso-integral mapping technique using magnetocardiogram, and its possible use for diagnosis of ischemic heart disease. Int J Card Imaging. 2000;16(1):55-66. [pmid: 10832626]. Exclude - Does not include a relevant device
Valouch R, Slavicek J, Tichy JA, et al. Electrocardiographic body surface maps (BSM) in patients with ischemic heart disease examined by coronary angiography. Prague Med Rep. 2004;105(2):131-140. Exclude - Does not include a relevant device
van Herpen G, Kors JA, Schijvenaars BJ. Are additional right precordial and left posterior ECG leads useful for the diagnosis of right ventricular infarct and posterior infarct? Also a plea for the revival of vectorcardiography. J Electrocardiol. Suppl. 1999;32:51-54. [pmid: 10688302]. Exclude - Does not present original data
Van Leeuwen P, Hailer B, Lange S, et al. Spatial distribution of repolarization times in patients with coronary artery disease. Pacing Clin Electrophysiol. 2003;26(8):1706-1714. [pmid: 12877704]. Exclude - Does not include a relevant device
Van Leeuwen P, Hailer B, Lange S, et al. Identification of patients with coronary artery disease using magnetocardiographic signal analysis. Biomed Tech (Berl). 2006;51(2):83-88. [pmid: 16915770]. Exclude - Does not include a relevant device
Vila J, Presedo J, Delgado M, et al. SUTIL: intelligent ischemia monitoring system. Int J Med Inform. 1997;47(3):193-214. [pmid: 9513008]. Exclude - Does not present original data
Wagner G, Pahlm O, Selvester R. Consideration of the 24-lead electrocardiogram to provide ST-elevation myocardial infarction equivalent criteria for acute coronary occlusion. J Electrocardiol. 2006;39(4 Suppl):S62-S67. [pmid: 17015069]. Exclude - Does not present original data
Wagner GS, Pahlm-Webb U, Pahlm O. Use of the 24-lead “standard” electrocardiogram to identify the site of acute coronary occlusion. A review paper. J Electrocardiol. 2008;41(3):238-244. [pmid: 18433615]. Exclude - Does not present original data
Walker SJ, Bell AJ, Loughhead MG, et al. Spatial distribution and prognostic significance of ST segment potential determined by body surface mapping in patients with acute inferior myocardial infarction. Circulation. 1987;76(2):289-297. [pmid: 3608118]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Weiss M, Narasimhadevara SM, Feng GQ, et al. Computer-enhanced frequency-domain and 12-lead electrocardiography accurately detect abnormalities consistent with obstructive and nonobstructive coronary artery disease. Heart Dis. 2002;4(1):2-12. [pmid: 11975826]. Exclude - Does not address target population, or address diagnosing CAD, ischemia, or ACS
Winters SL, Beacken M, Ip J, et al. Tweaking the signal-averaged electrocardiogram in search of improved predictive accuracy. J Am Coll Cardiol. 1992;20(1):151-152. [pmid: 1607516]. Exclude - Does not present original data
Wong CK. Detecting ST deviations: Does body surface mapping help or have we missed information from lead aVR?. Int J Cardiol. 2011;152(3):403-407. [pmid: 21917324]. Exclude - Does not present original data
Wung SF, Drew B. Comparison of 18-lead ECG and selected body surface potential mapping leads in determining maximally deviated ST lead and efficacy in detecting acute myocardial ischemia during coronary occlusion. J Electrocardiol. Suppl. 1999;32:30-37. [pmid: 10688300]. Exclude - Does not include a relevant device
Wung SF, Lux RL, Drew BJ. Thoracic location of the lead with maximal ST-segment deviation during posterior and right ventricular ischemia: comparison of 18-lead ECG with 192 estimated body surface leads. J Electrocardiol. Suppl. 2000;33:167-174. [pmid: 11265718]. Exclude - Does not include a relevant device
Xue J, Aufderheide T, Scott Wright R, et al. Added value of new acute coronary syndrome computer algorithm for interpretation of prehospital electrocardiograms. J Electrocardiol. Suppl. 2004;37:233-239. [pmid: 15534847]. Exclude - Does not include a relevant device
Yamada S, Yamaguchi I. Magnetocardiograms in clinical medicine: unique information on cardiac ischemia, arrhythmias, and fetal diagnosis. Intern Med. 2005;44(1):1-19. [pmid: 15704657]. Exclude - Does not present original data
Yang H. Multiscale recurrence quantification analysis of spatial cardiac vectorcardiogram signals. IEEE Trans Biomed Eng. 2011;58(2):339-347. [pmid: 20693104]. Exclude - Does not include a relevant device
Yanowitz FG, Vincent GM, Lux RL, et al. Application of body surface mapping to exercise testing: S-T80 isoarea maps in patients with coronary artery disease. Am J Cardiol. 1982;50(5):1109-1113. [pmid: 7137038]. Exclude - Does not include a relevant device
Yasui S, Kubota I, Ohyama T, et al. Diagnosis of coronary artery disease by body surface mapping--body surface distribution of exercise-induced ST changes in patients without myocardial infarction. Jpn Circ J. 1985;49(7):727-732. [pmid: 4057537]. Exclude - Does not include a relevant device
Zanchi E, Turitto G, Risa AL, et al. Absence of correlation between late potentials on the signal averaged electrocardiogram and transient myocardial ischemia. New Trends in Arrhythmias. 1990;6(1–2):145-149. Exclude - Does not include a relevant device
Zizzo C, Hassani A, Turner D. Automatic detection and imaging of ischemic changes during electrocardiogram monitoring. IEEE Trans Biomed Eng. 2008;55(3):1243-1247. [pmid: 18334423]. Exclude - Does not present original data