# Quality Assessment Criteria and Ratings

## Quality Assessment of Diagnostic Accuracy Studies (QUADAS) Tool

For each question answer Yes, No, or Unclear. A user’s guide explaining each question and how to score your responses is available in the 2003 QUADAS article here: http://www.biomedcentral.com/1471-2288/3/25

1. Was the spectrum of patients representative of the patients who will receive the test in practice?
2. Were selection criteria clearly described?
3. Is the reference standard likely to correctly classify the target condition?
4. Is the time period between reference standard and index test short enough to be reasonably sure that the target condition did not change between the two tests?
5. Did the whole sample or a random selection of the sample, receive verification using a reference standard of diagnosis?
6. Did patients receive the same reference standard regardless of the index test result?
7. Was the reference standard independent of the index test (i.e. the index test did not form part of the reference standard)?
8. Was the execution of the index test described in sufficient detail to permit replication of the test?
9. Was the execution of the reference standard described in sufficient detail to permit its replication?
10. Were the index test results interpreted without knowledge of the results of the reference standard?
11. Were the reference standard results interpreted without knowledge of the results of the index test?
12. Were the same clinical data available when test results were interpreted as would be available when the test is used in practice?
13. Were uninterpretable/ intermediate test results reported?
14. Were withdrawals from the study explained?

### Additional quality criteria considered

15. Were patients selected as a random or consecutive sample?
16. Was the first author funded by the manufacturer of the device?
17. Does the abstractor have concerns about conflict of interest (COI)?

Please describe any other study quality assessments not covered in the above questions.

## Overall Assessment of Study Quality

Assign the study an overall quality rating based on the following definitions:

Good (low risk of bias). No major features that risk biased results. RCTs are considered a high study design type, but studies that include consecutive patients representative of the intended sample for whom diagnostic uncertainty exists may also meet this standard. A “good” study avoids the multiple biases to which medical test studies are subject (e.g. use of an inadequate reference standard, verification bias), and key study features are clearly described, including the comparison groups, measurement of outcomes, and the characteristics of patients who failed to actual state (diagnostic or prognosis) verified.

Fair (moderate risk of bias). Susceptible to some bias, but flaws not sufficient to invalidate the results. The study does not meet all the criteria required for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.

Poor (high risk of bias). Significant flaws that imply biases of various types that may invalidate the results. The study has significant biases determined a priori to be major of “fatal” (i.e. likely to make the results either uninterpretable or invalid).

Quality Rating:

___ Good ___ Fair ___ Poor

If the study is rated as “Fair” or “Poor,” provide rationale for decision.

Table D-1 presents the summary rating and results for the overall quality rating, the 14 QUADAS questions, and an additional 3 questions considered during the review.

Table D-1 Quality assessment for the 11 included studies (14 articles)

Study ID | Overall Quality Rating | Patient Representation | Selection Criteria | Reference Standard | Time Interval | Sample for Verification | Reference test uniformly applied | Reference test independently performed | Index Test Replicability | Reference Test Replicability | Index Test Blinded Interpretation | Reference Test Blinded Interpretation | Clinical Data Availability | Uninterpretable or Intermediate Test Reporting | Study Withdrawal Description | Random or Consecutive Sample | Author Funded by Manufacturer | Conflict of Interest
Carley et al., 2005 | Fair | Y | Y | N | Y | Y | Y | Y | N | Y | Y | Y | Y | N | Y | N | Y | Y
Fermann et al., 2009 | Fair | Y | Y | N | Y | U | N | Y | Y | Y | Y | Y | Y | N | N | Y | N | N
Maynard et al., 2003 | Fair | Y | Y | N | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | Y | Y | U | N
McClelland et al., 2003 | Fair | Y | U | U | Y | Y | Y | Y | U | U | U | U | Y | U | Y | U | U | Y
Menown et al., 1998 | Fair | Y | N | N | Y | Y | U | Y | Y | N | U | U | Y | U | Y | N | N | N
Menown et al., 2001 | Fair | N | Y | N | N | Y | Y | Y | Y | Y | U | U | Y | N | Y | Y | N | N
Michaelides et al., 1999 | Fair | N | Y | Y | Y | Y | Y | Y | Y | N | U | U | Y | Y | Y | Y | U | U
O'Neil et al., 2010 and Hoekstra et al., 2009 | Good | Y | Y | Y | Y | Y | N | Y | Y | Y | Y | Y | Y | Y | Y | Y | U | Y
Ornato et al., 2009 | Fair | N | Y | N | Y | Y | Y | Y | Y | N | Y | Y | Y | U | Y | Y | U | U
Owens et al., 2008 and Owens et al., 2004 | Fair | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N
Owens et al., 2006 and Navarro et al., 2003 | Fair | N | Y | U | Y | Y | Y | U | Y | Y | Y | Y | Y | N | Y | Y | U | U

Abbreviations: N=No; U=Unclear; Y=Yes

## Reference List of Included Studies

Carley SD, Jenkins M, Mackway Jones K. Body surface mapping versus the standard 12 lead ECG in the detection of myocardial infarction amongst emergency department patients: a Bayesian approach. Resuscitation. 2005;64(3):309-314. [pmid: 15733759].
Fermann GJ, Lindsell CJ, O’Neil BJ, et al. Performance of a body surface mapping system using emergency physician real-time interpretation. Am J Emerg Med. 2009;27(7):816-822. [pmid: 19683110].
Hoekstra JW, O’Neill BJ, Pride YB, et al. Acute detection of ST-elevation myocardial infarction missed on standard 12-Lead ECG with a novel 80-lead real-time digital body surface map: primary results from the multicenter OCCULT MI trial. Ann Emerg Med. 2009;54(6):779-788 e1. [pmid: 19766352].
Maynard SJ, Menown IB, Manoharan G, et al. Body surface mapping improves early diagnosis of acute myocardial infarction in patients with chest pain and left bundle branch block. Heart. 2003;89(9):998-1002. [pmid: 12923008].
Mcclelland A, Owens C, Menown IB, et al. Comparison of the 80-lead body surface map to physician and to 12-lead electrocardiogram in detection of acute myocardial infarction. Am J Cardiol. 2003;92(3):252-257. [pmid: 12888126].
Menown IB, Allen J, Anderson J, et al. ST depression only on the initial 12-lead ECG: early diagnosis of acute myocardial infarction. Eur Heart J. 2001;22(3):218-227. [pmid: 11161933].
Menown IB, Patterson R, MacKenzie G, et al. Body-surface map models for early diagnosis of acute myocardial infarction. J Electrocardiol. Suppl. 1998;31:180-188. [pmid: 9988026].
Michaelides AP, Dilaveris PE, Psomadaki ZD, et al. QRS prolongation on the signal-averaged electrocardiogram versus ST-segment changes on the 12-lead electrocardiogram: which is the most sensitive electrocardiographic marker of myocardial ischemia?. Clin Cardiol. 1999;22(6):403-408. [pmid: 10376179].
Navarro C, Owens C, Riddell J, et al. The use of calculated epicardial potentials improves significantly the sensitivity of a diagnostic algorithm in the detection of acute myocardial infarction. J Electrocardiol. Suppl. 2003;36:127-132. [pmid: 14716613].
O’Neil BJ, Hoekstra J, Pride YB, et al. Incremental benefit of 80-lead electrocardiogram body surface mapping over the 12-lead electrocardiogram in the detection of acute coronary syndromes in patients without ST-elevation myocardial infarction: Results from the Optimal Cardiovascular Diagnostic Evaluation Enabling Faster Treatment of Myocardial Infarction (OCCULT MI) trial. Acad Emerg Med. 2010;17(9):932-939. [pmid: 20836773].
Ornato JP, Menown IB, Peberdy MA, et al. Body surface mapping vs 12-lead electrocardiography to detect ST-elevation myocardial infarction. Am J Emerg Med. 2009;27(7):779-784. [pmid: 19683104].
Owens C, McClelland A, Walsh S, et al. Comparison of value of leads from body surface maps to 12-lead electrocardiogram for diagnosis of acute myocardial infarction. Am J Cardiol. 2008;102(3):257-265. [pmid: 18638583].
Owens C, McClelland A, Walsh S, et al. Prehospital 80-LAD mapping: does it add significantly to the diagnosis of acute coronary syndromes?. J Electrocardiol. Suppl. 2004;37:223-232. [pmid: 15534846].
Owens C, Navarro C, McClelland A, et al. Improved detection of acute myocardial infarction using a diagnostic algorithm based on calculated epicardial potentials. Int J Cardiol. 2006;111(2):292-301. [pmid: 16368156].