# Inclusion and Exclusion Criteria

Table C-1 Summary of inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | - Symptomatic patients at low to intermediate risk (“symptomatic” defined as any symptom that gives the diagnosing physician suspicion of ACS/CAD/ischemia); - Population can include both symptomatic and asymptomatic patients if data for symptomatic patients were reported separately; - Population can include both high-risk and low-to-intermediate risk patients if data for low-to-intermediate risk patients were reported separately; - Patients all ≥18 years of age, or if some patients <18, data for patients ≥18 must be presented separately | - Study addresses only asymptomatic or high-risk patients; - Sample size <20 patients
Devices | - Obtains and interprets electrical activity from the heart (ECG-based); - Utilizes standard 12-lead information or has additional leads (e.g., body surface mapping); - Transforms/interprets electrical signal in a novel way. Data transformation into spatial imaging or through advanced mathematics (e.g., Fast Fourier Transform) to produce new indexes that are relevant; - Claimed to be useful for diagnosing CAD, ACS, or detecting myocardial ischemia; - Commercially available in the United States; - Has received FDA approval or clearance for marketing | - Purpose of device use in the study is only to detect arrhythmias.; - Does not address diagnosing CAD, ischemia, or ACS
Outcomes | - Performance characteristics of the device; - Effects on diagnostic or treatment decisions; - Effects on patient outcomes of interest:; - catheterization laboratory findings; - clinical outcomes of mortality; - cardiac symptoms; - function and functional status; - therapeutic interventions | None
Setting | - Implementation of the device in most medical facilities must be feasible; - Studies that occur in the catheterization laboratory may be included if all other criteria are met | Implementation of the device requires facilities that are not typically available in most medical facilities in the United States
Publications | - English language articles; - Peer-reviewed, full-length publication of original data (relevant followup studies and subgroup analyses meet criteria for inclusion) | - Articles not published in English, or not peer-reviewed; - Not original data (e.g., editorials, letters to the editor, opinion pieces). Systematic reviews and meta-analyses were excluded from abstraction but were hand-searched as potential sources of additional material if relevant to the topic.

Abbreviations: ACS=acute coronary syndrome; CAD=coronary artery disease; ECG=electrocardiogram; FDA=U.S. Food and Drug Administration