# Search Terms

Table B-1 PubMed search (November 18, 2011)

Set | Terms | Results
1 | ("acute coronary syndrome"[MeSH Terms] OR "acute coronary syndrome"[All Fields]) OR ("myocardial ischemia"[MeSH Terms] OR "myocardial ischemia"[All Fields] OR (("myocardium"[MeSH Terms] OR "myocardium"[All Fields] OR "myocardial"[All Fields]) AND ("ischaemia"[All Fields] OR "ischemia"[MeSH Terms] OR "ischemia"[All Fields])) OR ("coronary disease"[MeSH Terms] OR "coronary artery disease"[MeSH Terms]) OR "coronary artery disease"[All Fields]) | 349665
2 | "electrocardiography"[MeSH Terms] OR "electrocardiography"[All Fields] OR "ecg"[All Fields] OR "ekg"[All Fields] OR "electrocardiogram"[All Fields] | 189506
3 | "Signal Processing, Computer-Assisted"[Mesh] OR "signal averaged"[All Fields] OR "signal averaging"[All Fields] OR "signal analysis"[All Fields] OR "signal processing"[All Fields] OR "signal interpretation"[All Fields] OR "spectral analysis"[All Fields] OR "body surface potential mapping"[All Fields] OR "body surface map"[All Fields] OR "body surface mapping"[All Fields] | 59800
4 | (((cardiag[All Fields] AND 112.2[All Fields]) OR (cardiag[All Fields] AND 128.1[All Fields]) OR (lux[All Fields] AND 32[All Fields]) OR (LUX[All Fields] AND 192[All Fields]) OR (parma[All Fields] AND 219[All Fields]) OR (Prime[All Fields] AND ("electrocardiography"[MeSH Terms] OR "electrocardiography"[All Fields] OR "ecg"[All Fields])) OR (Procardio[All Fields] AND 8[All Fields]) OR (VCM[All Fields] AND 3000[All Fields]) OR (Visual[All Fields] AND ("electrocardiography"[MeSH Terms] OR "electrocardiography"[All Fields] OR "ecg"[All Fields])) OR cardio3kg[All Fields]) OR (3DMP[All Fields] AND MCG[All Fields]) OR MultiFunction-CardioGram[All Fields] OR (hyperQ[All Fields] OR (cardiologic[All Fields] AND ("Explorer (Kansas City) "[Journal] OR "Explorer (Hayward) "[Journal] OR "explorer"[All Fields])) OR (("blood vessels"[MeSH Terms] OR ("blood"[All Fields] AND "vessels"[All Fields]) OR "blood vessels"[All Fields] OR "vascular"[All Fields]) AND ("Explorer (Kansas City) "[Journal] OR "Explorer (Hayward) "[Journal] OR "explorer"[All Fields]))) OR ((31[All Fields] AND channel[All Fields] AND biomagnetometer[All Fields]) OR (83[All Fields] AND ("decapodiformes"[MeSH Terms] OR "decapodiformes"[All Fields] OR "squid"[All Fields]) AND (mcg[All Fields] AND meg[All Fields])) OR (("Clin Microbiol Infect"[Journal] OR "cmi"[All Fields]) AND 2409[All Fields]) OR (("Clin Microbiol Infect"[Journal] OR "cmi"[All Fields]) AND Magnetocardiograph[All Fields]) OR (("Mod Churchm"[Journal] OR "mc"[All Fields]) AND 6400[All Fields])) OR ((fdx[All Fields] AND 6521[All Fields]) OR (MAC[All Fields] AND 5000[All Fields]) OR (MAG[All Fields] AND 12[All Fields])) OR (((model[All Fields] AND 1200[All Fields]) OR (mcg[All Fields] AND 7[All Fields])) AND (("electrocardiography"[MeSH Terms] OR "electrocardiography"[All Fields] OR "ecg"[All Fields]) OR ("electrocardiography"[MeSH Terms] OR "electrocardiography"[All Fields] OR "ekg"[All Fields]) OR ("electrocardiography"[MeSH Terms] OR "electrocardiography"[All Fields] OR "electrocardiogram"[All Fields]) OR ("electrocardiography"[MeSH Terms] OR "electrocardiography"[All Fields]) OR ("magnetocardiography"[MeSH Terms] OR "magnetocardiography"[All Fields])))) OR (3DMP[All Fields] OR (("arrhythmias, cardiac"[MeSH Terms] OR ("arrhythmias"[All Fields] AND "cardiac"[All Fields]) OR "cardiac arrhythmias"[All Fields] OR "arrhythmia"[All Fields]) AND ("research"[MeSH Terms] OR "research"[All Fields]) AND ("technology"[MeSH Terms] OR "technology"[All Fields])) OR 1200EPX[All Fields] OR (fukuda[All Fields] AND denshi[All Fields])) | 2899
5 | #1 AND #2 AND (#3 OR #4) | 2354
6 | #1 AND #2 AND (#3 OR #4) limits: English | 1969
7 | Animals[mh] NOT Humans[mh] | 3616211
8 | #6 NOT #7 | 1834
9 | "magnetocardiography"[MeSH Terms] OR "magnetocardiography"[All Fields] OR cardiogoniometry[All Fields] OR (high[All Fields] AND "frequency"[All Fields] AND QRS[title/abstract]) | 914
10 | #1 AND #2 AND (#3 OR #4 OR #9) limits: English | 2055
11 | #10 NOT #7 | 1912

Table B-2 Embase search (November 18, 2011)

Set | Terms | Results
1 | 'acute coronary syndrome'/exp OR 'acute coronary syndrome' OR 'coronary artery disease'/exp OR 'coronary artery disease' OR 'silent myocardial ischemia'/exp OR 'silent myocardial ischemia' OR 'heart muscle ischemia'/exp OR 'heart muscle ischemia’ | 260820
2 | 'electrocardiogram'/exp OR 'electrocardiogram' OR 'electrocardiography monitoring'/exp OR 'electrocardiography monitoring' OR 'ecg'/exp OR ecg OR 'ekg'/exp OR ekg OR 'electrocardiography'/exp OR electrocardiography | 259395
3 | 'cardiag 112.2':ab OR 'cardiag 128.1':ab OR 'lux 32':ab OR 'lux 192':ab OR 'parma 219':ab OR 'prime ecg':ab OR 'procardio 8':ab OR 'vcm 3000':ab OR 'visual ecg':ab OR 'cardio3kg':ab OR 'cardx':ab OR mfemt:ab OR 'multifunction-cardiogram':ab OR cardiamax:ab OR cardiosoft:ab OR hyperq:ab OR 'cardiologic explorer':ab OR 'vascular explorer':ab OR '31 channel biomagnetometer':ab OR '83 squid':ab OR 'cmi 2409':ab OR 'cmi magnetocardiograph':ab OR 'mc 6400':ab OR 'squid magnometer':ab OR 'fdx 6521':ab OR 'mac 5000':ab OR 'mag 12':ab OR 'model 1200':ab OR primeecg:ab OR 3dmp:ab OR 'arrhythmia research technology':ab OR 1200epx:ab OR 'fukuda denshi':ab OR 'mcg 7':ab | 128
4 | 'spectral analysis':ti OR 'spectral analysis':ab | 13775
5 | 'signal averaged':ti OR 'signal averaging':ti OR 'signal analysis':ti OR 'signal processing':ti OR 'signal interpretation':ti OR 'body surface potential mapping':ti OR 'body surface map':ti OR 'body surface mapping':ti OR 'signal averaged':ab OR 'signal averaging':ab OR 'signal analysis':ab OR 'signal interpretation':ab OR 'body surface map':ab OR 'body surface mapping':ab OR 'signal processing':ab OR 'body surface potential mapping':ab | 9465
6 | 'signal processing'/exp | 48964
7 | 'magnetocardiography':ti OR cardiogoniometry:ti OR 'magnetocardiography':ab OR 'cardiogoniometry':ab OR 'high frequency qrs':ti OR 'high frequency qrs':ab OR 'magnetocardiography'/exp | 772
8 | #3 OR #4 OR #5 OR #6 OR #7 | 68739
9 | #1 AND #2 AND #8 | 777
10 | #1 AND #2 AND #8 AND [humans]/lim AND [english]/lim | 548
11 | #1 AND #2 AND #8 AND [humans]/lim AND [english]/lim AND [embase]/lim NOT [medline]/lim | 87

Table B-3 Cochrane library search (November 18, 2011)

Set | Terms | Results
1 | (acute coronary syndrome):ti,ab,kw or (coronary artery disease):ti,ab,kw or (myocardial ischemia):ti,ab,kw | 10785
2 | MeSH descriptor Acute Coronary Syndrome explode all trees | 409
3 | MeSH descriptor Coronary Artery Disease explode all trees | 2103
4 | MeSH descriptor Myocardial Ischemia explode all trees | 19050
5 | #1 OR #2 OR #3 OR #4 | 21953
6 | (signal averaged):ti,ab,kw or (signal averaging):ti,ab,kw or (signal analysis):ti,ab,kw or (signal processing):ti,ab,kw or (signal interpretation):ti,ab,kw | 2100
7 | (spectral analysis):ti,ab,kw or (body surface potential mapping):ti,ab,kw or (body surface map):ti,ab,kw or (body surface mapping):ti,ab,kw | 844
8 | "cardiag 112.2" OR "cardiag 128.1" OR "lux 32" OR "lux 192" OR "parma 219" OR "prime ecg" OR "procardio 8" OR "vcm 3000" OR "visual ecg" OR "cardio3kg" OR "cardx" OR mfemt OR "multifunction-cardiogram" OR cardiamax OR cardiosoft OR hyperq OR "cardiologic explorer" OR "vascular explorer" OR "31 channel biomagnetometer" OR "83 squid" OR "cmi 2409" OR "cmi magnetocardiograph" OR "mc 6400" OR "squid magnometer" OR "fdx 6521" OR "mac 5000" OR "mag 12" OR "model 1200" OR primeecg OR 3dmp OR "arrhythmia research technology" OR 1200epx OR "fukuda denshi": OR "mcg 7" | 9
9 | MeSH descriptor Signal Processing, Computer-Assisted explode all trees | 762
10 | #6 OR #7 OR #8 OR #9 | 2895
11 | MeSH descriptor Electrocardiography explode all trees | 7042
12 | (ecg):ti,ab,kw or (ekg):ti,ab,kw or (electrocardiogram):ti,ab,kw or (electrocardiology):ti,ab,kw | 5473
13 | #10 AND (#11 OR #12) | 519
14 | #5 AND #10 AND (#11 OR #12) ** Cochrane reviews= 0 / Other reviews=1 / Clinical Trials= 122 / Economic evaluations= 1 | 126**
15 | Limited to Cochrane Database of Systematic Reviews and Database of Abstracts of Reviews of Effects | 1