# Gray Literature Search Strategy

Table A-1 Gray literature sources, search terms, and results

Source | Search terms | Restrictions | Number of Citations Identified | Unique Devices Identified
General gray literature sources
Google search www.google.com | ("ECG" OR "electrocardiogram" OR "EKG") AND [("signal averaging" OR "signal averaged" OR "signal analysis" OR "spectral") OR ("body surface mapping") OR (“body surface potential mapping”) OR (“body surface potential map”) OR (“mathematical analysis”)] NOT (3DMP, MCG, mfEMT) (“magnetocardiography” AND (ischemia OR ACS OR CAD) NOT CardioMag) (“HF-QRS” OR “HF QRS” or “HFQRS” OR “cardiogoniometry) | - In the title of the page; - Published between May 1, 2009, and May 25, 2011; - English language; - Anywhere on the page; - Published between Jan 1, 2000, and Jun 8, 2011; - English language; - Anywhere on the page; - Published between Jan 1, 2000, and Jun 8, 2011; - English language | 689 988 123 | - Cardiag 112.2; - Cardiag 128.1; - Corazonix Predictor System; - CarDx; - CardioSoft, CardiaMax; - Cardioscape 3.0; - Visual 3Dx; - Procardio 8; - Cardiologic/Vascular explorer; - Pagewriter Xli (Philips); - Megacart Recording Device (Siemens-Elema AB); - Lux-32/Lux-192; - ActiveTwo System (Biosemi); - CMI-Magnetocardiograph (Magiscan); - MCG07 (MaGIC); - 83-SQUID MCG/MEG; - 31-channel biomagnetometer (Philips); - MC-6400 (Hitachi); - MAG12 (Marquette)
Food and Drug Administration (FDA) documents searched via: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm | Product codes: DPS and DRW | Posted between Jan 1, 2007, and May 25, 2011 | 71 | - Easi ECG (Philips) (DRW) - 2004; - PRIME ECG
Patents advanced search via: www.freepatentsonline.com | (“cardiac” AND “spectral”) AND (“electrocardiograph” OR “electrocardiogram”) “body surface mapping” AND “ischemia” | - Previous 20 years; - Word stemming on; - US Patents only; - Search performed June 8, 2011 | 1057 42 | 0 0
Online search of all AHA journals via advanced search page: http://circ.ahajournals.org/search.dtl | “signal analysis” OR “signal averaged” OR “signal averaging” OR “body surface map” OR “body surface mapping” OR “mathematical analysis” OR “magnetocardiography” OR “HF-QRS” OR “HF QRS” OR “HFQRS OR “cardiogoniometry” | - In title or abstract; - Published between Jul 2007 and May 2011; - All AHA journal titles and abstracts | 32 | 0
Online search of all journals of the American College of Cardiology (ACC): http://www.acc.org Search page: http://content.onlinejacc.org/search.dtl | “signal averaging” OR “signal averaged” OR “surface mapping” OR “body surface map” OR “magnetocardiography” OR “HF-QRS” OR “HF QRS” OR “HFQRS” OR “cardiogoniometry” “mathematics analysis” OR “mathematical analysis” AND (ischemia OR CAD) | - In title or abstract; - All JACC journals; - Published between Jul 2007 and May 2011 | 35 | - MAC 5000 (GE Medical); - CARTO system (Biosense-Webster): electroanatomical voltage mapping
Abstracts from professional society meetings
American Heart Association (AHA) Abstract Archive tool search portal: http://www.abstractsonline.com/arch/home.aspx?lookupkey=12345 | “cardiac spectral” OR “body surface mapping” OR “signal averaging” OR “mathematical analysis” OR “magnetocardiography” OR “HF-QRS” OR “HF QRS” OR “HFQRS” OR “cardiogoniometry” | Abstract Archive tool searches across all AHA-sponsored scientific meetings through 2006 | 56 | - VCM 3000
Heart Rhythm Society Annual Scientific Sessions: http://www.hrsonline.org/Sessions/ Search page: http://www.abstracts2view.com/hrs/ | All of the words: (“electrocardiogram” AND (“signal averaging” OR “signal averaged”) OR “spectral analysis” OR “body surface mapping”) OR “magnetocardiography” OR “HF-QRS” OR “HF QRS” OR “HFQRS” OR “cardiogoniometry” | All abstract categories 2007 to 2011 | 38 | 0
European Society of Cardiology (ESC) Congress Abstracts: http://www.escardio.org/Pages/index.aspx Search page: http://spo.escardio.org/abstract-book/topic.aspx | Any of the following: “signal-averaged”, “body surface”, “electrocardiograph”, “ECG”, “magnetocardiography”, “HF-QRS”, “HF QRS”, “HFQRS”, “cardiogoniometry” | 2007 to 2010 | - Active2 (BioSemi); - BioSemi Mark-6; - Nijegen 64-lead system; - CardioMapp (Prucka Engineering Inc, Houston, TX); - FP-705 LP (Fukuda Denshi, Tokyo); - 120 lead BSPM; - Vectorcardiogram: Frank Lead System | 279
trial registry
ClinicalTrials.gov: http://www.clinicaltrials.gov/ Basic Search: http://www.clinicaltrials.gov/ct2/search | “ischemia” AND [(“electrocardiograph” OR “electrocardiogram”) OR “signal-averaged” OR “body surface mapping” OR “magnetocardiography” OR “HF-QRS” OR “HF QRS” OR “HFQRS” OR “cardiogoniometry”] | - None; - Search performed May 26, 2011 | 94 | - HyperQ; - Micro T wave alternans detection devices; - Magnetocardiograph by CardioMag

Abbreviations: BSPM=body surface potential mapping