# Executive Summary

## Introduction

Coronary artery disease (CAD) is one of the leading causes of mortality in the United States.1 One of the most common manifestations of clinically significant CAD is chest pain resulting from cardiac ischemia or myocardial infarction (MI). While chest pain is a common symptom of patients presenting to clinics and emergency departments, only about 6 percent of patients presenting to the emergency room with acute chest pain are ultimately diagnosed with MI.2 Identifying which patients with chest pain are experiencing acute ischemic heart disease is critical since a delay in diagnosis can impede the application of effective therapies such as thrombolytic agents or primary percutaneous coronary intervention (PCI). The most reliable diagnostic test for CAD is coronary angiography, but exercise or pharmacological stress tests can also help identify patients with clinically significant CAD.

Patients who present for medical attention with chest pain or other symptoms that suggest acute ischemia or infarction are often considered to have acute coronary syndrome (ACS). ACS typically serves as a “working diagnosis” for patients suspected of having ischemic heart disease, pending the establishment or ruling out of specific diagnoses.2 The first and potentially most important test typically administered in the workup of a patient with symptoms suggestive of ACS is the standard, resting 12-lead electrocardiogram (ECG). Typically, the ECG will indicate ST elevation myocardial infarction (STEMI), or it will be normal or nondiagnostic. If the ECG indicates STEMI, the patient will most likely be taken directly to coronary angiography without additional testing. In contrast, a normal or nondiagnostic ECG result does not rule out the possibility of acute ischemia or infarction, so further testing is usually indicated if the clinical presentation suggests ischemic heart disease. Patients without ST elevation on the initial ECG who are ultimately found via further testing (e.g., elevated cardiac biomarkers, stress testing, or other tests) to have had an MI are diagnosed as having had non-ST elevation myocardial infarction (NSTEMI). Patients without ST elevation on the initial ECG who subsequently show evidence (e.g., by stress testing) of reversible myocardial ischemia are usually given the diagnosis of unstable angina. In sum, patients without ST elevation whose clinical presentation suggests a cardiac etiology are typically considered to have ACS.

Although the standard ECG is critically important in the initial evaluation of patients with ACS, it is limited in its ability to correctly identify all patients with acute ischemic heart disease. False-positive test results are likely to lead to further testing or initiation of treatment, or both, whereas false-negative test results may lead to adverse outcomes associated with delay or withholding of potentially life-saving interventions. New devices that seek to improve on the standard ECG’s capabilities in the evaluation of patients presenting with chest pain have been developed. An enhanced ECG-based test that allows a patient with ACS to be accurately identified could potentially limit the myocardial damage associated with delays in administering acute reperfusion treatment (by improving on the standard ECG’s true-positive rate), while possibly minimizing the use of potentially harmful invasive testing among patients who do not have clinically significant CAD (by improving on the standard ECG’s false-positive rate). The test performance and diagnostic accuracy efficacy of these technologies as well as their impact on clinical decisionmaking and patient outcomes, however, is uncertain.

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Duke Evidence-based Practice Center (Contract No. HHSA 290-2007-10066-I). The purpose of this technology assessment is to summarize the clinical and scientific evidence for commercially available ECG-based signal analysis technologies used to evaluate patients with chest pain or other symptoms suggestive of ACS among patients at low to intermediate risk for CAD. Although some ECG-based technologies have been used for other purposes (e.g., detecting malignant arrhythmias), these are not the focus of the current report—as defined in our inclusion/exclusion criteria. Rather, this report focuses on patients who do not meet STEMI or STEMI-equivalent criteria on the standard 12-lead ECG.

We synthesized the existing literature on these technologies in response to the following key questions (KQs):

### KQ 1

a. What devices and methods for ECG-based signal analysis are used, or proposed to be used, for diagnosis of CAD and/or acute coronary syndrome (with or without chest pain) in outpatient settings (including physician offices, urgent care, and emergency departments) in patients at low to intermediate risk? What is the U.S. Food and Drug Administration (FDA) status of these devices?
b. What are considered the “gold standard” tests for the diagnosis of CAD and/or acute coronary syndrome (with or without chest pain) in patients at low to intermediate risk, and what are their strengths and limitations?

### KQ 2

a. What is the evidence for inter-rater, intra-rater, intra-patient, and intra-device variability?
b. What is the evidence for diagnostic test performance compared to the reference standard used in the study? What factors (confounders) affect test sensitivity and specificity?
c. What is the evidence that ECG-based signal analysis technologies impact diagnostic decisionmaking?
d. What is the evidence that ECG-based signal analysis technologies impact patient outcomes?

## Methods

We used a two-step searching approach to systematically identify devices and literature relevant to this review. First, potentially relevant technologies were identified through a search of gray literature sources, including the U.S. FDA Web site, Google™, www.freepatentsonline.com, www.clinicialtrials.gov, and the abstracts of various scientific meetings, and a targeted review of selected relevant journal websites (Appendix A) . From this body of data, we sought to identify devices that may improve the diagnosis of CAD and/or ACS through the use of signal analysis, spectral analysis, or other forms of advanced data transformation. Second, terms for devices identified through the gray literature scan or prior knowledge from previous work3 were added to detailed strategies developed to search English-language literature indexed in PubMed, Embase, and Cochrane Database of Systematic Reviews and Database of Abstracts of Reviews of Effects from database inception through November 18, 2011 (Appendix B). Searches conducted in these databases were designed to identify peer-reviewed publications presenting evidence regarding test performance, decisionmaking, or patient outcomes. The reference list of a similar review conducted in 2010^3^ was manually hand-searched and cross-checked against our library of search results, and additional citations retrieved for screening.

Two investigators independently reviewed titles, abstracts, and full-text articles against pre-specified criteria to determine eligibility. The general eligibility criteria for our review included:

- A relevant device must be a physical device (i.e., not simply computer software) that obtains and interprets information about the electrical activity of the heart in ways that are different from the standard 12-lead ECG.
- The device must have been approved or cleared for marketing by the U.S. FDA.
- The device must be commercially available in the United States.
- Implementation of the device in most medical facilities must be feasible.
- The device must be tested in patients at low to intermediate risk for CAD who have a clinical presentation consistent with ACS.
- The study must report relevant outcomes including performance characteristics compared with an acceptable reference standard, effects on diagnostic or treatment decisions, or effects on patient outcomes.

We excluded studies that reported data only from patients known to have ST elevation by standard ECG, or studies that did not report data separately for patients with and without ST elevation at the time of the initial ECG. We excluded studies that included patients under 18 years of age, if data for the patients 18 years and older were not presented separately. We also excluded studies that included a previously scheduled coronary angiogram as an eligibility criterion for patients; the rationale for this exclusion was that a patient population preselected for coronary angiography is likely to include a relatively high proportion of individuals at high risk for CAD or ischemic heart disease—and as such does not represent the target population for this report. We excluded devices for which we could not find evidence of commercial availability. A complete table of study inclusion and exclusion criteria is presented in Appendix C.

To aid in standardization of data collection from included studies, investigators received data abstraction instructions directly on each form created specifically for this project. We designed these forms to collect the data required to evaluate eligibility criteria for inclusion in this review, test characteristics, and effects on outcomes of interest. One investigator abstracted data from each included study and assessed study quality and applicability; the results were then reviewed for accuracy by a second investigator. Data were synthesized qualitatively and, when appropriate, using quantitative methods.

Investigators assessed the quality of each study according to the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) tool,4–6 including characteristics of sample selection, adequate description of the index and reference tests, blinded interpretation of the index and reference tests, and presence of verification bias (Appendix D). To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of Good, Fair, and Poor based on the study’s adherence to well-accepted standard methodologies (such as QUADAS) and adequate reporting standards (refer to Table D-1 in Appendix D).

Device performance was summarized using sensitivity, specificity, and likelihood ratios. Test sensitivity describes the proportion of subjects with disease who have an abnormal test. Test specificity describes the proportion of subjects without disease who have a normal test. A likelihood ratio is a measure that may be more useful to clinicians since a simple nomogram allows posttest disease probabilities to be readily calculated. The positive likelihood ratio describes how many times more likely it is that an abnormal test comes from a patient with disease versus a patient without disease. The negative likelihood ratio describes how many times more likely it is that a normal test comes from a patient with disease versus a patient without disease. The posttest probabilities for negative and positive results were calculated on the basis of assumed prevalence and positive and negative likelihood ratios obtained from the meta-analysis. A positive likelihood ratio greater than 10 and a negative likelihood ratio less than 0.1 imply strong effects, whereas a likelihood ratio close to 1 implies no effect. Positive and negative likelihood ratios with corresponding confidence intervals for each diagnostic method were calculated from the mean logit-sensitivity and mean logit-specificity and their corresponding standard errors.

When studies were conceptually homogeneous, we used a bivariate random-effects generalized linear regression model to compute summary estimates of sensitivity and specificity with 95 percent confidence intervals.7 A random-effects model assumes that variability is a result of sampling errors as well as the true differences between studies and provides a meta-analytic modeling approach for pooling sensitivity and specificity, while accounting for possible correlation between sensitivities and specificities of the studies included.8 For studies that derived a test algorithm in a training set and tested performance in a validation set, we analyzed performance characteristics from the validation set. We evaluated statistical heterogeneity by inspecting forest plots and computing Q and I^2^ statistics. Since the Q test is underpowered, we set the threshold for significant heterogeneity at p<0.10. For the I^2^ test, a suggested interpretation is to assign the terms low, moderate, and high to I^2^ values of 25 percent, 50 percent, and 75 percent, respectively9.

## Results

### Key Question 1a Devices and Methods for ECG-based Signal Analysis

The combined gray and published literature searches identified eight potentially relevant devices that are available for purchase in the United States and have been cleared for marketing by the FDA, including four that use signal averaging, one that uses body surface mapping, one that uses mathematical analysis, and two that use high-frequency QRS analysis. The names of the eight devices and their manufacturers are as follows: Predictor^®^ and Model 1200 EPX™; by Arrhythmia Research Technology; MAC^®^ 5000 by GE Medical; LP 3000 by Fidelity Medical; the PRIME ECG^®^ by Heartscape Technologies; 3DMP™/MCG™/mfEMT™ by Premier Heart; CardioSoft^®^ by NASA; and HyperQ™ by Biological Signal Processing.

### Key Question 1b Gold Standard Tests

#### Coronary Artery Disease

Current guidelines from the American College of Cardiology/American Heart Association (ACC/AHA) maintain that coronary angiography remains the best reference standard for diagnosing CAD.10 Through interrogation and identification of the coronary anatomy, coronary angiography is the best available test to identify which patients may benefit from surgical or percutaneous intervention, medical management, or both. Among low-risk patients who are typically not referred for coronary angiography but who undergo clinical observation and/or noninvasive testing instead, several noninvasive diagnostic tests have served as an acceptable reference standard. In these patients, results from noninvasive tests have correlated with the incidence of cardiovascular events. In particular, stress tests (with or without imaging) provide clinicians with incremental risk prediction that informs management and treatment decisions. Stress tests also provide prognostically important data that have been associated with patient outcomes, such as exercise capacity, hemodynamic response, and magnitude of ST segment abnormalities.

According to the ACC/AHA consensus guideline, the standard, resting 12-lead ECG is not an acceptable reference standard for the diagnosis of CAD.11 The standard ECG detects electrocardiac signals emitted by myocardial cells, but it cannot directly detect the presence of atherosclerotic plaques in the coronary arteries. Consequently, the standard ECG demonstrates poor accuracy in diagnosing patients at low to intermediate risk for CAD. New technologies for diagnosing CAD are therefore most appropriately compared to the reference standard of coronary angiography or, at the very least, acceptable noninvasive reference standards such as stress imaging. Appropriate use of biomarkers, on the other hand, is an acceptable reference standard for the diagnosis of acute MI but not of CAD. Table ES-1 summarizes how current guidelines10–15 maintain that coronary angiography remains the preferred reference standard for the diagnosis of CAD, while exercise stress testing with imaging serves as an acceptable reference standard.

#### Acute Coronary Syndrome

ACS is a term commonly used to describe the clinical presentation that includes acute onset of chest pain or other symptoms that suggest myocardial ischemia or infarction. ACS typically serves as a working diagnosis for such patients, pending the establishment or ruling out of specific diagnoses. As such, there is no gold standard test for ACS. The standard ECG serves as one of the most important tests in the initial evaluation of patients who present with symptoms suggestive of ACS, but additional clinical and laboratory information is required to accurately differentiate patients with and without acute ischemic heart disease. Elevations in serum biomarkers such as creatine kinase (CK) MB fraction or troponin-I may indicate ischemia or infarct of the myocardium and may be used as an acceptable but imperfect reference standard for the diagnosis of ACS (Table ES-1).

Table ES-1 Potential reference standards for diagnosing CAD^a^ or ACS

Reference Standard | Level of Acceptability
CAD
Coronary angiography | Preferred
Stress testing with imaging | Acceptable
Imaging studies without exercise or pharmacological stress; - Resting 12-lead ECG; - Stress testing with ECG | Unacceptable
ACS
Biomarkers (applicable only for identifying myocardial injury) | Acceptable

a Based on current guidelines.10–15

Abbreviations: ACS=acute coronary syndrome; CAD=coronary artery disease; ECG=electrocardiogram

### Key Question 2a Evidence for Variability by Rater, Patient, or Device

Our search strategy did not identify any eligible studies that reported information about intra-rater, intra-patient, or intra-device variability. We identified a single fair-quality study that evaluated the inter-rater variability of the PRIME ECG body surface mapping (BSM) device. This study involved 150 eligible patients with acute chest pain who underwent both standard ECG and PRIME ECG testing in an emergency department setting. Complete data were available for 135 patients. Emergency physicians and BSM experts interpreted the BSM readings as either “negative” (for normal readings) or “positive” (for abnormal readings). Of these 135 readings, emergency physicians and BSM experts agreed on 52 (39%) of the negative test result readings and 63 (47%) of the positive test result readings. Fifteen (11%) BSM tests were interpreted as negative by emergency physicians but positive by BSM experts, and 5 (4%) BSM tests were interpreted as positive by emergency physicians but negative by BSM experts. This corresponds to a kappa statistic of 0.63 (95% confidence interval [CI], 0.53 to 0.72).

### Key Question 2b Evidence for Test Performance

We identified 11 studies represented by 14 articles that evaluated the test performance of 2 eligible devices. The PRIME ECG was evaluated in 10 studies involving patients with chest pain recruited from emergency departments, medical wards, or mobile coronary care units; 8 of these studies also evaluated the 12-lead ECG. Some of the patients were treated in mobile coronary care units in Ireland, and as such may have been at high risk for CAD, thereby resulting in a study population that may be at higher overall risk for CAD than the target population for this report. The PRIME ECG was compared to cardiac biomarkers for the presence of acute myocardial injury.

A bivariate random-effects model was used to combine results of nine of these studies after excluding one study that was a subset of other studies and as such had duplicate data. The sensitivity and specificity were 71.1 percent (95% CI, 45.6 to 87.8) and 90.2 percent (CI, 83.2 to 94.4), respectively. Studies were statistically heterogeneous for the positive likelihood ratio (Q=122.9, df=9, p<0.001; I^2^=92.7%) and the negative likelihood ratio (Q=314.9, df=9, p<0.001; I^2^=97.1%). The summary estimate for the positive likelihood ratio was 6.3 (CI, 3.3 to 12.1) and for the negative likelihood ratio was 0.30 (CI, 0.16 to 0.56).

We performed a sensitivity analysis excluding two studies, namely, the first in a series of studies in which a different diagnostic algorithm was used 16, and a second study with a very small sample size that was disproportionately weighted in the random effects meta-analysis.17. The standard errors of the effect measures are determined by two factors—the number of subjects and the measure of interest in the compared groups. These factors in turn determine the weight given to a study in the meta-analysis. If one or both factors differ (are outliers) from the other studies included, the results can be overestimated or underestimated.18 The sensitivity and specificity for the remaining studies were 68.4 percent (CI, 35.1 to 89.7) and 91.4 percent (CI, 83.6 to 95.7), respectively. The remaining studies were heterogeneous for the positive likelihood ratio (Q=122.1, df=7, p<0.001, I^2^=94.3%) and negative likelihood ratio (Q=277.4, df=7, p<0.001, I^2^=97.5%). The positive likelihood ratio (6.7; CI, 2.8 to 15.9) and negative likelihood ratio (0.31; CI, 0.14 to 0.69) were not substantially changed. Using these latter estimates of test performance, an abnormal PRIME ECG test in a patient with a pretest probability for clinically significant CAD of 50 percent, would yield a posttest probability of 87.0 percent. A normal PRIME ECG would yield a posttest probability of 23.7 percent. The performance characteristics of the 12-lead ECG were not statistically significantly different from the PRIME ECG.

One other eligible device, the LP 3000, was evaluated by one study included in this report. The LP 3000 signal averaging system was compared to a 12-lead ECG in 126 consecutive patients referred to a hospital for a first episode of typical angina. The LP 3000 system was found to have a sensitivity and specificity of 70 percent and 89 percent, respectively, compared with 56 percent and 89 percent for ST changes detected by 12-lead ECG. The improved sensitivity of signal averaging ECG relative to 12-lead ECG was statistically significant (p<0.01).

### Key Question 2c Evidence for Impact on Diagnostic Decisionmaking

Our search did not identify any eligible studies providing evidence that the use of, or findings from, ECG-based technologies other than the standard 12-lead ECG had an impact on the decisions or actions of patients or health care providers.

### Key Question 2d Evidence for Impact on Patient Outcomes

We identified a single, good-quality study that addressed this question among a population of patients at moderate to high risk for CAD. The multicenter, prospective, cohort-blinded Optimal Cardiovascular Diagnostic Evaluation Enabling Faster Treatment of Myocardial Infarction (OCCULT MI) trial evaluated the PRIME ECG among 1830 adults at moderate to high risk for adverse cardiovascular outcomes who presented to a tertiary care emergency department with chest pain or symptoms suspicious for ACS. The primary aim of this study was to test the hypothesis that individuals with STEMI detected only by the PRIME ECG would have similar angiographic pathology and similar mortality and morbidity rates to those with STEMI detected by standard ECG. A preplanned secondary analysis compared outcomes of patients with STEMI to patients without STEMI. Among the 1514 patients with available outcome data, ST elevation detected by the PRIME ECG was associated with increased mortality (odds ratio [OR] 11.2; 95% CI, 1.8 to 67). ST elevation on a standard 12-lead ECG, however, was not predictive of adverse outcomes in this population.

We identified a fair-quality study that collected information about the impact of testing on patient outcomes but did not report those outcomes. That study collected information obtained from patients through the course of their hospital stay and after discharge (such as repeat visit to the emergency department with chest pain or ischemic symptoms, recurrent MI, catheterization, revascularization, or death). These patient outcomes, however, where not reported in the published paper.

## Discussion

Currently, there is little evidence for the utility of ECG-based signal analysis technologies as a diagnostic test among patients at low to intermediate risk for CAD who present in the outpatient setting with the chief complaint of chest pain or other symptoms suggestive of ACS. Most devices identified by our gray literature search did not appear to have published articles describing their performance among the target population for this report. The literature was not sufficient to determine if factors such as sex, body type, medications, and comorbid medical conditions affected test performance.

All but one of the included studies were rated as fair quality, primarily because of the difficulty in blinding decisionmakers from available and pertinent data that may have influenced the course of evaluation or treatment of patients with ACS. The OCCULT MI study was rated as good quality because the investigators successfully minimized bias introduced by health care providers and because they used study-adjudicated diagnoses as the reference standard.

The limited available evidence demonstrates proof of concept, particularly for the PRIME ECG device, and it suggests that the sensitivity of body surface mapping and signal averaging devices is higher compared with standard ECG for identifying patients with ACS who have either ischemic heart disease or CAD. However, this evidence is limited by the use of incomplete reference standards in the published studies, including elevated biomarkers for detecting acute ischemic heart disease.

Further research is needed to better describe the performance characteristics of these devices to determine in what circumstances, if any, these devices might precede, replace, or add to the standard ECG in test strategies to identify patients with clinically significant CAD in the patient population of interest. To fully assess the impact of these devices on the diagnostic strategies for patients with chest pain, test performance needs to be linked to clinically important outcomes through modeling or longitudinal studies.

## References

1 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart disease and stroke statistics—2012 update: a report from the American Heart Association. Circulation. 2012;125(1):e2-e220. [pmid: 22179539].
2 Hamm CW, Bassand JP, Agewall S, et al. ESC Guidelines for the management of acute coronary syndromes in patients presenting without persistent ST-segment elevation: The Task Force for the management of acute coronary syndromes (ACS) in patients presenting without persistent ST-segment elevation of the European Society of Cardiology (ESC). Eur Heart J. 2011. [pmid: 21873419].
3 Coeytaux RR, Williams JW, Chung E, et al. Centers for Medicare and Medicaid Services. ECG-based Signal Analysis Technologies. Technology Assessment Report. Agency for Healthcare Research and Quality. 2010.
4 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Medical Research Methodology. 2006;6:9. [pmid: 16519814].
5 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Medical Research Methodology. 2003;3:25. [pmid: 14606960].
6 Whiting P, Harbord R, Kleijnen J, et al. No role for quality scores in systematic reviews of diagnostic accuracy studies. BMC Medical Research Methodology. 2005;5:19. [pmid: 15918898].
7 Harbord RM, Whiting P, Sterne JA, et al. An empirical comparison of methods for meta-analysis of diagnostic accuracy showed hierarchical models are necessary. J Clin Epidemiol. 2008;61(11):1095-1103. [pmid: 19208372].
8 Menke J. Bivariate random-effects meta-analysis of sensitivity and specificity with SAS PROC GLIMMIX. Methods Inf Med. 2010;49(1):54-62. 62. 64. [pmid: 19936437].
9 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-560. [pmid: 12958120].
10 Bashore TM, Bates ER, Berger PB, et al. American College of Cardiology/Society for Cardiac Angiography and Interventions Clinical Expert Consensus Document on cardiac catheterization laboratory standards. A report of the American College of Cardiology Task Force on Clinical Expert Consensus Documents. J Am Coll Cardiol. 2001;37(8):2170-2214. [pmid: 11419904].
11 Kadish AH, Buxton AE, Kennedy HL, et al. ACC/AHA clinical competence statement on electrocardiography and ambulatory electrocardiography. A report of the ACC/AHA/ACP-ASIM Task Force on Clinical Competence (ACC/AHA Committee to Develop a Clinical Competence Statement on Electrocardiography and Ambulatory Electrocardiography). J Am Coll Cardiol. 2001;38(7):2091-2100. [pmid: 11738321].
12 American College of Radiology, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, et al. ACCF/ACR/SCCT/SCMR/ASNC/NASCI/SCAI/SIR 2006 appropriateness criteria for cardiac computed tomography and cardiac magnetic resonance imaging. A report of the American College of Cardiology Foundation Quality Strategic Directions Committee Appropriateness Criteria Working Group. Journal of the American College of Radiology. 2006;3(10):751-771. [pmid: 17412166].
13 Braunwald E, Antman EM, Beasley JW, et al. ACC/AHA guidelines for the management of patients with unstable angina and non-ST-segment elevation myocardial infarction. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on the Management of Patients With Unstable Angina). [erratum appears in J Am Coll Cardiol 2001 Jul;38(1):294-5]. J Am Coll Cardiol. 2000;36(3):970-1062. [pmid: 10987629].
14 Dennie CJ, Leipsic J, Brydie A. Canadian Association of Radiologists: Consensus Guidelines and Standards for Cardiac CT. Can Assoc Radiol J. 2009;60(1):19-34. [pmid: 19433026].
15 Klocke FJ, Baird MG, Lorell BH, et al. ACC/AHA/ASNC guidelines for the clinical use of cardiac radionuclide imaging—executive summary: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (ACC/AHA/ASNC Committee to Revise the 1995 Guidelines for the Clinical Use of Cardiac Radionuclide Imaging). J Am Coll Cardiol. 2003;42(7):1318-1333. [pmid: 14522503].
16 Menown IB, Patterson R, MacKenzie G, et al. Body-surface map models for early diagnosis of acute myocardial infarction. J Electrocardiol. Suppl. 1998;31:180-188. [pmid: 9988026].
17 Menown IB, Allen J, Anderson J, et al. ST depression only on the initial 12-lead ECG: early diagnosis of acute myocardial infarction. Eur Heart J. 2001;22(3):218-227. [pmid: 11161933].
18 Tang JL. Weighting bias in meta-analysis of binary outcomes. J Clin Epidemiol. 2000;53(11):1130-1136. [pmid: 11106886].