# Abbreviations and Acronyms

ACS: acute coronary syndrome
AHRQ: Agency for Healthcare Research and Quality
BSM: body surface mapping
CAD: coronary artery disease
CCT: cardiac computed tomography
CCU: cardiac care unit
CI: confidence interval
CK-MB: creatine kinase-MB fraction
CMS: Centers for Medicare and Medicaid Services
ECG: electrocardiogram
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
KQ: key question
LR+: positive likelihood ratio
LR−: negative likelihood ratio
MI: myocardial infarction
NSTEMI: non-ST elevation myocardial infarction
PCI: percutaneous coronary intervention
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
ROC: receiver operating characteristic
SA: signal averaging
STEMI: ST elevation myocardial infarction
WHO: World Health Organization