# Peer Reviewers

We wish to acknowledge the individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Ethan Balk, M.D., M.P.H.
  Associate Director, Tufts Evidence-based Practice Center
  Tufts Medical Center
  Boston, MA 02111
- W. Kenneth Haisty Jr., M.D.
  Cardiologist
  Wake Forest Baptist Medical Center
  Winston-Salem, NC 27157
- Humberto J. Vidaillet, M.D.
  Cardiologist
  Marshfield Clinic
  Marshfield, WI 54449