# References

1 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart disease and stroke statistics—2012 update: a report from the American Heart Association. Circulation. 2012;125(1):e2-e220. [pmid: 22179539].
2 Hamm CW, Bassand JP, Agewall S, et al. ESC Guidelines for the management of acute coronary syndromes in patients presenting without persistent ST-segment elevation: The Task Force for the management of acute coronary syndromes (ACS) in patients presenting without persistent ST-segment elevation of the European Society of Cardiology (ESC). Eur Heart J. 2011. [pmid: 21873419].
3 Patel MR, Peterson ED, Dai D, et al. Low diagnostic yield of elective coronary angiography. N Engl J Med. 2010;362(10):886-895. [pmid: 20220183].
4 Canadian Cardiovascular Society, American Academy of Family Physicians, American College of Cardiology, et al. 2007 focused update of the ACC/AHA 2004 guidelines for the management of patients with ST-elevation myocardial infarction: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines.[erratum appears in J Am Coll Cardiol. 2008 Mar 4;51(9):977]. J Am Coll Cardiol. 2008;51(2):210-247. [pmid: 18191746].
5 Bossaert L, O'Connor RE, Arntz HR, et al. Part 9: Acute coronary syndromes: 2010 International Consensus on Cardiopulmonary Resuscitation and Emergency Cardiovascular Care Science with Treatment Recommendations. Resuscitation. Suppl 1. 2010;81:e175-e212. [pmid: 20959169].
6 Mirvis DM, Goldberger AL. Libby P, Bonow RO, Mann DL, et al., editors. Chapter 12 - Electrocardiography. Braunwald's heart disease: a textbook of cardiovascular medicine. 8th ed. Philadelphia. Saunders. 2008:149-194. PMID:.
7 Holubkov R, Pepine CJ, Rickens C, et al. Electrocardiogram abnormalities predict angiographic coronary artery disease in women with chest pain: results from the NHLBI WISE Study. Clin Cardiol. 2002;25(12):553-558. [pmid: 12492124].
8 Ammar KA, Kors JA, Yawn BP, et al. Defining unrecognized myocardial infarction: a call for standardized electrocardiographic diagnostic criteria. Am Heart J. 2004;148(2):277-284. [pmid: 15308997].
9 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. 1991;11(2):88-94. [pmid: 1907710].
10 Coeytaux RR, Williams JW, Chung E, et al. Centers for Medicare and Medicaid Services. ECG-based Signal Analysis Technologies. Technology Assessment Report. Agency for Healthcare Research and Quality. 2010.
11 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Medical Research Methodology. 2006;6:9. [pmid: 16519814].
12 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Medical Research Methodology. 2003;3:25. [pmid: 14606960].
13 Whiting P, Harbord R, Kleijnen J, et al. No role for quality scores in systematic reviews of diagnostic accuracy studies. BMC Medical Research Methodology. 2005;5:19. [pmid: 15918898].
14 Harbord RM, Whiting P, Sterne JA, et al. An empirical comparison of methods for meta-analysis of diagnostic accuracy showed hierarchical models are necessary. J Clin Epidemiol. 2008;61(11):1095-1103. [pmid: 19208372].
15 Menke J. Bivariate random-effects meta-analysis of sensitivity and specificity with SAS PROC GLIMMIX. Methods Inf Med. 2010;49(1):54-62. 62. 64. [pmid: 19936437].
16 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-560. [pmid: 12958120].
17 Blue Cross Blue Shield of North Carolina. Available at: www.bcbsnc.com/assets/services/public/pdfs/medicalpolicy/electrocardiographic_body_surface_mapping.pdf. Accessed February 20, 2012.
18 Michaelides AP, Dilaveris PE, Psomadaki ZD, et al. QRS prolongation on the signal-averaged electrocardiogram versus ST-segment changes on the 12-lead electrocardiogram: which is the most sensitive electrocardiographic marker of myocardial ischemia?. Clin Cardiol. 1999;22(6):403-408. [pmid: 10376179].
19 Simson MB. Use of signals in the terminal QRS complex to identify patients with ventricular tachycardia after myocardial infarction. Circulation. 1981;64(2):235-242. [pmid: 7249291].
20 Spackman TN, Abel MD, Schlegel TT. Twelve-lead high-frequency QRS electrocardiography during anesthesia in healthy subjects. Anesth Analg. 2005;100(4):1043-1047. [pmid: 15781519].
21 Schupbach WM, Emese B, Loretan P, et al. Non-invasive diagnosis of coronary artery disease using cardiogoniometry performed at rest. Swiss Med Wkly. 2008;138:15-16. 230. 238. [pmid: 18431698].
22 Tonino PA, De Bruyne B, Pijls NH, et al. Fractional flow reserve versus angiography for guiding percutaneous coronary intervention. N Engl J Med. 2009;360(3):213-224. [pmid: 19144937].
23 Alderman EL, Corley SD, Fisher LD, et al. Five-year angiographic follow-up of factors associated with progression of coronary artery disease in the Coronary Artery Surgery Study (CASS). CASS Participating Investigators and Staff. J Am Coll Cardiol. 1993;22(4):1141-1154. [pmid: 8409054].
24 Boden WE, O'Rourke RA, Teo KK, et al. Optimal medical therapy with or without PCI for stable coronary disease. N Engl J Med. 2007;356(15):1503-1516. [pmid: 17387127].
25 Chaitman BR, Fisher LD, Bourassa MG, et al. Effect of coronary bypass surgery on survival patterns in subsets of patients with left main coronary artery disease. Report of the Collaborative Study in Coronary Artery Surgery (CASS). Am J Cardiol. 1981;48(4):765-777. [pmid: 7025604].
26 Patel MR, Dehmer GJ, Hirshfeld JW, et al. ACCF/SCAI/STS/AATS/AHA/ASNC 2009 Appropriateness Criteria for Coronary Revascularization: a report by the American College of Cardiology Foundation Appropriateness Criteria Task Force, Society for Cardiovascular Angiography and Interventions, Society of Thoracic Surgeons, American Association for Thoracic Surgery, American Heart Association, and the American Society of Nuclear Cardiology Endorsed by the American Society of Echocardiography, the Heart Failure Society of America, and the Society of Cardiovascular Computed Tomography. J Am Coll Cardiol. 2009;53(6):530-553. [pmid: 19195618].
27 Ringqvist I, Fisher LD, Mock M, et al. Prognostic value of angiographic indices of coronary artery disease from the Coronary Artery Surgery Study (CASS). J Clin Invest. 1983;71(6):1854-1866. [pmid: 6863543].
28 Gibbons RJ, Balady GJ, Bricker JT, et al. ACC/AHA 2002 guideline update for exercise testing: summary article. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1997 Exercise Testing Guidelines).[erratum appears in J Am Coll Cardiol. 2006 Oct 17;48(8):1731]. J Am Coll Cardiol. 2002;40(8):1531-1540. [pmid: 12392846].
29 Bashore TM, Bates ER, Berger PB, et al. American College of Cardiology/Society for Cardiac Angiography and Interventions Clinical Expert Consensus Document on cardiac catheterization laboratory standards. A report of the American College of Cardiology Task Force on Clinical Expert Consensus Documents. J Am Coll Cardiol. 2001;37(8):2170-2214. [pmid: 11419904].
30 Klocke FJ, Baird MG, Lorell BH, et al. ACC/AHA/ASNC guidelines for the clinical use of cardiac radionuclide imaging—executive summary: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (ACC/AHA/ASNC Committee to Revise the 1995 Guidelines for the Clinical Use of Cardiac Radionuclide Imaging). J Am Coll Cardiol. 2003;42(7):1318-1333. [pmid: 14522503].
31 Kadish AH, Buxton AE, Kennedy HL, et al. ACC/AHA clinical competence statement on electrocardiography and ambulatory electrocardiography. A report of the ACC/AHA/ACP-ASIM Task Force on Clinical Competence (ACC/AHA Committee 42 to Develop a Clinical Competence Statement on Electrocardiography and Ambulatory Electrocardiography). J Am Coll Cardiol. 2001;38(7):2091-2100. [pmid: 11738321].
32 American College of Radiology, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, et al. ACCF/ACR/SCCT/SCMR/ASNC/NASCI/SCAI/SIR 2006 appropriateness criteria for cardiac computed tomography and cardiac magnetic resonance imaging. A report of the American College of Cardiology Foundation Quality Strategic Directions Committee Appropriateness Criteria Working Group. Journal of the American College of Radiology. 2006;3(10):751-771. [pmid: 17412166].
33 Miller JM, Rochitte CE, Dewey M, et al. Diagnostic performance of coronary angiography by 64-row CT. N Engl J Med. 2008;359(22):2324-2336. [pmid: 19038879].
34 Dennie CJ, Leipsic J, Brydie A. Canadian Association of Radiologists: Consensus Guidelines and Standards for Cardiac CT. Can Assoc Radiol J. 2009;60(1):19-34. [pmid: 19433026].
35 Braunwald E, Antman EM, Beasley JW, et al. ACC/AHA guidelines for the management of patients with unstable angina and non-ST-segment elevation myocardial infarction. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on the Management of Patients With Unstable Angina).[erratum appears in J Am Coll Cardiol 2001 Jul;38(1):294-5]. J Am Coll Cardiol. 2000;36(3):970-1062. [pmid: 10987629].
36 Scirica BM, Morrow DA, Scirica BM, et al. Troponins in acute coronary syndromes. Seminars in Vascular Medicine. 2003;3(4):363-374. [pmid: 15199443].
37 Bennett NM, Paris MC. Black ER, Bordley DR, Tape TG, et al., editors. Cardiovascular problems: coronary artery disease. Diagnostic strategies for common medical problems. 2nd ed. Philadelphia. Amercian College of Physicians-American Society of Internal Medicine. 1999:47-60. PMID:.
38 Anonymous. Guidelines for cardiac exercise testing. ESC Working Group on Exercise Physiology, Physiopathology and Electrocardiography. European Heart Journal. 1993;14(7):969-988. [pmid: 8375424].
39 Fermann GJ, Lindsell CJ, O'Neil BJ, et al. Performance of a body surface mapping system using emergency physician real-time interpretation. Am J Emerg Med. 2009;27(7):816-822. [pmid: 19683110].
40 Menown IB, Patterson R, MacKenzie G, et al. Body-surface map models for early diagnosis of acute myocardial infarction. J Electrocardiol. Suppl. 1998;31:180-188. [pmid: 9988026].
41 Menown IB, Allen J, Anderson J, et al. ST depression only on the initial 12-lead ECG: early diagnosis of acute myocardial infarction. Eur Heart J. 2001;22(3):218-227. [pmid: 11161933].
42 Mcclelland A, Owens C, Menown IB, et al. Comparison of the 80-lead body surface map to physician and to 12-lead electrocardiogram in detection of acute myocardial infarction. Am J Cardiol. 2003;92(3):252-257. [pmid: 12888126].
43 Navarro C, Owens C, Riddell J, et al. The use of calculated epicardial potentials improves significantly the sensitivity of a diagnostic algorithm in the detection of acute myocardial infarction. J Electrocardiol. Suppl. 2003;36:127-132. [pmid: 14716613].
44 Owens C, McClelland A, Walsh S, et al. Prehospital 80-LAD mapping: does it add significantly to the diagnosis of acute coronary syndromes?. J Electrocardiol. Suppl. 2004;37:223-232. [pmid: 15534846].
45 Owens C, McClelland A, Walsh S, et al. Comparison of value of leads from body surface maps to 12-lead electrocardiogram for diagnosis of acute myocardial infarction. Am J Cardiol. 2008;102(3):257-265. [pmid: 18638583].
46 Carley SD, Jenkins M, Mackway Jones K. Body surface mapping versus the standard 12 lead ECG in the detection of myocardial infarction amongst emergency department patients: a Bayesian approach. Resuscitation. 2005;64(3):309-314. [pmid: 15733759].
47 Maynard SJ, Menown IB, Manoharan G, et al. Body surface mapping improves early diagnosis of acute myocardial infarction in patients with chest pain and left bundle branch 43 block. Heart. 2003;89(9):998-1002. [pmid: 12923008].
48 Ornato JP, Menown IB, Peberdy MA, et al. Body surface mapping vs 12-lead electrocardiography to detect ST-elevation myocardial infarction. Am J Emerg Med. 2009;27(7):779-784. [pmid: 19683104].
49 Owens C, Navarro C, McClelland A, et al. Improved detection of acute myocardial infarction using a diagnostic algorithm based on calculated epicardial potentials. Int J Cardiol. 2006;111(2):292-301. [pmid: 16368156].
50 O'Neil BJ, Hoekstra J, Pride YB, et al. Incremental benefit of 80-lead electrocardiogram body surface mapping over the 12-lead electrocardiogram in the detection of acute coronary syndromes in patients without ST-elevation myocardial infarction: Results from the Optimal Cardiovascular Diagnostic Evaluation Enabling Faster Treatment of Myocardial Infarction (OCCULT MI) trial. Acad Emerg Med. 2010;17(9):932-939. [pmid: 20836773].
51 Hoekstra JW, O'Neill BJ, Pride YB, et al. Acute detection of ST-elevation myocardial infarction missed on standard 12-Lead ECG with a novel 80-lead real-time digital body surface map: primary results from the multicenter OCCULT MI trial. Ann Emerg Med. 2009;54(6):779-788 e1. [pmid: 19766352].
52 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol. 2006;59(12):1331-1332. author reply 1332-3. [pmid: 17098577].
53 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58(10):982-990. [pmid: 16168343].
54 Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12(14):1293-1316. [pmid: 8210827].
55 Tang JL. Weighting bias in meta-analysis of binary outcomes. J Clin Epidemiol. 2000;53(11):1130-1136. [pmid: 11106886].
56 Borenstein M. Introduction to meta-analysis. Chichester, U.K. John Wiley & Sons. 2009.
57 Bossuyt PM, Irwig L, Craig J, et al. Comparative accuracy: assessing new tests against existing diagnostic pathways.[erratum appears in BMJ. 2006 Jun 10;332(7554):1368]. BMJ. 2006;332(7549):1089-1092. [pmid: 16675820].