# Acronyms

ACS: American Cancer Society

AHCPR: Agency for Health Care Policy and Research

AIDS: Acquired immunodeficiency syndrome

APAP: Acetaminophen

ARS: Adjective rating scale

AZT: Zidovudine, commonly referred to as AZT

CNS: Central nervous system

CSA: Controlled Substances Act

CSF: Cerebrospinal fluid

CT scan: Computed tomographic scan

EMLA: Eutectic mixture of local anesthetic

FDA: Food and Drug Administration

GI: Gastrointestinal

HIV: Human immunodeficiency virus

MAOI: Monamine oxidase inhibitors

MRI: Magnetic resonance imaging

NRS: Numerical rating scale

NSAID: Nonsteroidal anti-inflammatory drug

PCA: Patient-controlled analgesia

TENS: Transcutaneous electrical nerve stimulation

WHO: World Health Organization

VAS: Visual analogue scale